# PEER REVIEW COMENTS/AUTHOR RESPONSES

RESPONSE | REVIEWER COMMENT
1. Are the objectives, scope, and methods for this review clearly described?
Yes. This is a very well written report that reviewing the evidence available for the use of the current generation of left ventricular assist devices as destination therapy. Given the very limited published data on the subject, the authors have adequately addressed the three key questions required for this topic.
Yes
Yes
Yes. The methods are clearly described and are standard for this type of evaluation. However, it should be noted that there are factors inherent in ventricular assist devices (VADs) that importantly influence their evaluation in clinical trials. First, the control group in trials to date (e.g. optimal medical management group of the REMATCH trial) is critically ill. Survival of the control group in REMATCH was so poor that a medical control group will be considered ethically unacceptable for subsequent trials, unless the trial specifically examines less ill patients (e.g. the The Evaluation of VAD InterVEntion Before Inotropic Therapy [REVIVE-IT] trial cited in the report, which will examine class IIIB patients). The REVIVE-IT trial itself faces challenges with regard to patients that cross-over from medical to device management during the trial. Clinical trials of new VADs for class IV heart failure will use approved devices as the control group. The report recognizes this situation and its limitations. A second factor stems from the fact that the therapy cannot be blinded to the observers or the patient. The use of objective measures such as maximal oxygen consumption and six minute walk test is therefore particularly important to trials and their evaluation | We have added a statement about use of more objective endpoints to the section on page 11 about patient outcomes for KQ1. We believe that although more objective endpoints such as exercise tests would be useful given the inability to blind comparisons between devices and non-surgical medical therapy, it is very difficult to translate changes in maximal exercise test parameters to effects on patients’ lives. Subjective patient outcomes could be less of an issue in unblinded comparisons of devices.
Yes
Yes. I found this review to be well-written and focused. The objectives of the review were clearly defined, and were presented in logical and concise manner. The scope of the review was also well described and took proper account for lack of sufficient data to definitively answer one of the key points. The methods applied to the project were reasonable and consistent with evidence-based analysis of the data.
Yes. Objectives, scope and methods are clearly described and appropriate for the potential therapy being evaluated.
2. Is there any indication of bias in our synthesis of the evidence?
No
No
No
No
No
No. I could not perceive a detectable bias in the synthesis of the evidence. The authors are to be commended for a balanced approach to the key questions posed
No. Evaluation appears to be free of any bias and the Technical Expert Panel Members are noted experts capable of providing appropriate guidance and oversight
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Yes. The authors have reviewed most of the published and unpublished data on the subject from 1995 to October 2011. However, it would be useful to include in this document the additional information in the latest Quarterly Statistical Report from the Interagency Registry for Mechanically Assisted Circulatory Support (INTERMACS) available on their web site. According to this report, the total number of medical centers performing LVAD implantations for destination therapy have doubled from 69 to 135 as quoted by the authors (page 7, para 3, line 6). Moreover, over a fifth of all LVADs have been implanted for destination therapy. | Updated information from the fourth annual INTERMACS report has been added to the Registry section on page 7. In addition, the INTERMACS website is now referenced there to provide access to up-to-date information.
No. There are limited publications related to HeartMate II
No
Yes. The fourth INTERMACS report was published in the February issue of the Journal of Heart and Lung Transplantation. The information will not dramatically change the findings of the VA-ESP report, in my opinion. However, the report may want to include the citation. The HeartWare left ventricular assist device is currently under review by the FDA for the bridge-to-transplantation indication. It may be worth mentioning this device as a future consideration, primarily due to the pump’s small size. It was chosen for the REVIVE-IT trial. | Updated information from the fourth annual INTERMACS report has been added to the Registry section on page 7. In addition, the INTERMACS website is now referenced to provide access to up to date information. We have now mentioned the HeartWare by name when discussing ongoing studies on pages 3, 17 and 23.
Yes; 1. [underlined: Ann Thorac Surg.] 2011 Nov;92(5):1593–9; discussion 1599–600. Epub 2011 Oct 31.; Lessons learned from experience with over 100 consecutive HeartMate II left ventricular assist devices. [underlined: John R], [underlined: Kamdar F], [underlined: Eckman P], [underlined: Colvin-Adams M], [underlined: Boyle A], [underlined: Shumway S], [underlined: Joyce L], [underlined: Liao K].; 2. [underlined: J Heart Lung Transplant.] 2011 Aug;30(8):849–53. Epub 2011 Apr 29.; Arteriovenous malformation and gastrointestinal bleeding in patients with the HeartMate II left ventricular assist device. [underlined: Demirozu ZT], [underlined: Radovancevic R], [underlined: Hochman LF], [underlined: Gregoric ID], [underlined: Letsou GV], [underlined: Kar B], [underlined: Bogaev RC], [underlined: Frazier OH].; 3. [underlined: J Heart Lung Transplant.] 2012 Jan;31(1):1–8. Epub 2011 Oct 8.; Pre-operative and post-operative risk factors associated with neurologic complications in patients with advanced heart failure supported by a left ventricular assist device. [underlined: Kato TS], [underlined: Schulze PC], [underlined: Yang J], [underlined: Chan E], [underlined: Shahzad K], [underlined: Takayama H], [underlined: Uriel N], [underlined: Jorde U], [underlined: Farr M], [underlined: Naka Y], [underlined: Mancini D].; 4. [underlined: Ann Thorac Surg.] 2010 Oct;90(4):1270–7. Infectious complications in patients with left ventricular assist device: etiology and outcomes in the continuous-flow era. [underlined: Topkara VK], [underlined: Kondareddy S], [underlined: Malik F], [underlined: Wang IW], [underlined: Mann DL], [underlined: Ewald GA], [underlined: Moazami N]. | The first report listed was screened but not included in this review because only 17 out of the 130 cases were destination therapy. The second report listed was screened but not included this review because most cases were not destination therapy. The article does point out the need to consider the risk and incidence of gastrointestinal bleeding as an important patient outcome particularly with continuous flow devices. Information about this important patient outcome was extracted whenever it was reported by studies that were included in the review. The third report listed was published after the literature search was done. It was not included this review because most cases used the older pulsatile flow HeartMate device that has become obsolete. Furthermore, the report doesn’t provide enough information to determine the predictive accuracy of identified risk factors for neurological complications. Judging by the magnitude of the differences, most likely the identified risk factors will not turn out to provide adequate discrimination. The article does point out the need to consider the risk and incidence of neurological complications as an important patient outcome. Information about this important patient outcome was extracted whenever it was reported by studies that were included in the review. The fourth report listed was screened but not included this review because most cases weren’t destination therapy, and the report doesn’t provide much information about patient selection based on the risk of infectious complications. The article does point out the need to consider the risk and incidence of infectious complications as an important patient outcome. Information about this important patient outcome was extracted whenever it was reported by studies that were included in the review.
Yes. The authors may wish to review the following citation: “Moreno SG, Novielli N, Cooper NJ. Cost-effectiveness of the implantable left ventricular assist device HeartMate II for patients awaiting heart transplantation. J Heart Lung Transplant March 2012 (e-published ahead of print)”, and the accompanying editorial by MS Slaughter and JG Rogers, titled “Determining the cost-effectiveness of mechanical circulatory support” | We have carefully reviewed both of these citations and decided against adding this cost-effectiveness analysis to the results section of the report because it took a UK National Health Service payer perspective and only looked at LVAD use as a bridge to heart transplant, However, the Moreno 2012 article does provide a good example of what could be done in a future in terms of a probabilistic cost-effectiveness analysis, so we incorporated information about this study into the Recommendations for Future Research Section on page 24.
No. There are no significant publications that have been overlooked or additional publications not included that would add value to the evaluation of in any way change the conclusions that have been made.
4. Additional suggestions or comments
Minor comments: Page 4 bullet # 3, line3; correct “ventricular” Page 35, column 4; it is unclear for which comparison the HR for all –cause death within 30 days refers to? Page 37, column 4; Mean pulmonary pressure > or ≤ 25 mmHg? | Typographical error on page 4 corrected. The reference groups for the HR’s now have been noted. The article repeatedly states ≤ 25 as indicated. The authors considered a low mean pulmonary artery pressure to be an indicator of right heart failure although others have associated worse outcomes with higher pulmonary pressures that can precipitate right heart failure after implantation of a left ventricular assist device.
On page 23 you state “A consensus of health care providers and patients needs to be established for the level of predicted mortality that would generally preclude use of destination therapy.” Ideally, this would be based on data from randomized trials directly. Estimating the risk benefit of a VAD on sub-populations without trial data has a high potential for error. If economic studies determine a minimum survival threshold that must be achieved in order for VAD implantation to be cost-effective then it would be useful to develop studies to predict survival less than that threshold. For your recommendation to register patients I would state the name/details of registry as many will not read the text to figure out what you are talking about. They may assume you are suggesting the VA could/should start its own registry. | We agree and have revised the statement on page 23 to, “Ideally clinical trials would be done to show that use of a prediction model improves patient outcomes. This review did not find any established or proposed threshold for predicted risk that would preclude use of destination therapy or generally be acceptable to patients and health care providers.” The INTERMACS registry has now been specified.
The report was well written with appropriate supporting literature. With regard to Key Question #2, information from INTERMACS defines risk factors for death following implantation of a ventricular assist device. At this point in time, the information has not been reduced to a quantitative predictive nomogram, but probably will be in the near future. Dr. David Naftel at UAB can give the group a better estimation of the timeline for developing a system to predict outcome in mechanical circulatory assist patients. I have no additional comments or suggestions
I’ve added several references describing outcomes AFTER the clinical studies were concluded. You can see that outcomes are not as good for patients getting devices WITHOUT being enrolled in clinical studies. This is not an observation unique to this particular clinical problem, but I think it warrants more attention. I noticed that the comparison focused on the comparison of newer devices to older ones, based on the assumption that LVAD’s generally have been shown to improve survival v. nonsurgical management. But what about other outcomes? There is an alarming incidence of disabling strokes in patients with LVAD’s. How would this figure in a patient’s decision to have an LVAD implanted? Would patient’s be willing to accept a higher mortality with nonsurgical management in order to avoid the increased likelihood of a disabling stroke if an LVAD is implanted? (For this reason, issues of informed consent also warrant attention. Are patients being made aware of the high complication rates before agreeing to implantation? (I appreciate this was not part of the charge of the committee.) | Points well taken. Observational studies that directly compared outcomes in practice versus clinical trials were of interest as were reports of patient outcomes in case series. Many of these reports were from investigational sites and we couldn’t always tell if the report included or excluded patients that were enrolled in clinical trials. Hopefully, the INTERMACS registry data will provide better estimates of the incidences of all types of patient outcomes. The articles did not identify any additional patient outcomes that were not considered during the review.
Regarding Key Question 1, there is no debate that use of the HeartMate II LVAD as compared to the HeartMate XVE LVAD in appropriate candidates leads to better outcomes, and that if compared to medical therapy alone the outcomes would be more decidedly favorable. However it would be important for the reviewers to point out that overall survival for DT patients with a HeartMate II was still only 55% at 2 years. This point would be of relevance to readers of the review and to policy makers. It is possible, perhaps even likely, that subsequent registry data will show improvement in the 2 year survival for DT patients supported via HeartMate II devices. If future updates to this report are generated, such data would be of considerable importance and should be disseminated. I am aware of anecdotes reporting very high 1 year survival rates for DT LVAD patients (I believe from the INTERMACS data set) but to my knowledge these data are not yet published. Are there data regarding readmission rates for patients who have undergone DT LVAD implantation? Such data would also be of interest to VA leadership. High rates of readmission post-operatively could mitigate some of the otherwise considerable advantages of LVAD placement in this very ill population of patients. I am aware of anecdotal reports that LVAD patients average >5 hospital readmissions over the first postoperative year, but these are purely anecdotes. Data in this regard might be useful. I would agree with the authors that any patient who receives a DT LVAD via the Veterans Administration should be put into a robust data registry and that patient outcomes should be followed over time. I would submit that these patients perhaps should be entered into the VA surgical quality improvement database, which is strong and robust and already is established at every VA hospital with a surgical program on site. I would also consider whether current LVADs being placed by the VA as bridge to transplant should also be entered into a clinical database in order to track outcomes. On page 7, paragraph 1 of the report, the authors note criteria established by the Centers for Medicare and Medicaid Services for clinical centers planning to initiate a DT LVAD program. The criteria included participation in a data registry, minimum volume standards for the implanting surgeon, and facility disease-specific certification for VADs by The Joint Commission. While VA would probably not be compelled to follow such CMS guidelines, one wonders whether it would nevertheless be wise and prudent to do so both to insure quality of the program and to deflect external criticism which might be directed at the VA for undertaking such a complex endeavor. | The outcomes of using the HeartMate II as destination therapy study including the overall survival are summarized in the Executive Summary (page 3) and in the body of the report and evidence table. We have also cited other survival estimates in the report and added updated 2-year estimates from the INTERMACS registry on page 17. All estimates appear to be remarkably consistent with a trend to improved survival as patient selection and processes improve. Our search did not find good estimates of readmission rates or what complications caused them. The cost effectiveness estimates do include readmission rates of 0.21 per month for device therapy versus 0.13 for medical therapy, and the cost effectiveness ratio was sensitive to the presumed readmission rate as has been pointed out in the report. The VA surgical quality improvement data base has been added to the recommendation. We agree, and had summarized the CMS criteria and other guidelines in the report to facilitate consideration by VA policymakers.
My only additional comment would pertain to Key Question #2 regarding site characteristics associated with patient benefits or harm. There is a trend in the U.S for “non-transplant” centers to establish stand-alone LVAD DT programs. It is unclear if these programs that have minimal to no transplant experience and have little to no experience with implanting LVADs as BTT will have similar outcomes in an older and potentially sicker DT patient population. It is possible that the VA system will need to address the question of whether it is feasible, makes clinical or economic sense to allow a LVAD DT program in a VA hospital without an advanced heart failure program that includes experience and expertise in the evaluation of heart transplant patients. Hopefully there will be some data in the next 3 – 5 years to help resolve this issue.
5. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
Provide emphasis regarding how remarkable technologic advancements have resulted in improved device outcomes. CMS did not consider conditional reimbursement until after the Slaughter study was published.
No changes are needed.
I think that the report accurately depicts the status quo of mechanical circulatory support. The Joint Commission has a process for accrediting mechanical circulatory support programs that may be of interest to the Veterans Administration. The requirements for this specialized accreditation describe in detail the personnel, processes, and infra-structure that are required for a mechanical circulatory support program
The authors are to be congratulated for creation of a balanced, thoughtful and well written report.
No additional recommendations