# SEARCH STRATEGY

Database: Ovid MEDLINE(R) <1948 to October Week 3 2011>

Search Strategy:

1. exp Heart-Assist Devices/ or lvad.mp.
2. ventric$ assist.mp.
3. artificial ventricle.mp.
4. heartware.mp.
5. heartmate.mp.
6. novacor.mp.
7. coraide.mp.
8. lionheart.mp.
9. or/1–8
10. limit 9 to (english language and humans and yr=”1995 -Current”)
11. congestive heart failure.mp. or exp Heart Failure/ or cardiac failure.mp. or myocardial failure.mp. or ventricular dysfunction.mp. or exp Ventricular Dysfunction/
12. 10 and 11
13. limit 12 to (case reports or comment or editorial or letter)
14. 12 not 13