# TECHNICAL EXPERT PANEL MEMBERS

Inder Anand, MD, FRCP, DPhil

Director, Heart Failure Program

University of Minnesota Medical School

William Gunnar, MD, JD

National Director of Surgery

Department of Veterans Affairs

William Holman, MD

Chief, Surgical Services

Birmingham VA Medical Center

Gundars Katlaps, MD

Chief, Section of Cardiothoracic Surgery

Surgical Director, Programs of Heart Transplantation and Mechanical Assist Devices

ichmond McGuire VA Medical Center

Richard Schofield, MD, FACC

Chairman of Medicine

Malcolm Randal VA Medical Center

Chief, Medical Service

North Florida/South Georgia Veterans Health System

Josef Stehlik, MD

Director, VAMC Cardiac Transplant Program

VA Salt Lake City Health Care System