# SUMMARY AND DISCUSSION

We identified 18 RCTs and 3 observational studies in post-operative surgical and high-risk medical patients that evaluated the comparative effectiveness of IPCDs in reducing VTE events or that rated ease of use or adherence. Most studies compared IPCDs to anticoagulation. Only 3 RCTs in high-risk surgical patients directly compared different IPCDs; there were no head-to-head comparisons in high-risk medical patients. IPCDs were comparable to anticoagulation for major clinical outcomes, but confidence intervals were typically wide and clinically important differences could not be excluded. Subgroup analyses did not show significant differences by device location or mode of inflation. The current evidence base to guide selection of a specific device or type of device is limited, and comparative effectiveness studies are needed to address this gap in evidence. This meta-message is consistent with the findings from another review.30

In Table 3 and sections below, we summarize the main findings and strength of evidence by key question (KQ).

Table 3 Strength of Evidence for ICPD Effectiveness in Reducing VTE Events

Outcome | Strength of Evidence Domains | | | | Effect Estimate (95% CI)^*^ | Strength of Evidence
Outcome | | | | | Effect Estimate (95% CI)^*^ | Strength of Evidence
Outcome | No. of Studies (Patients) | Study Design/Risk of Bias | Consistency Directness | Precision Publication Bias | Effect Estimate (95% CI)^*^ | Strength of Evidence
KQ 1: IPCDs vs Anticoagulation in Surgical Patients
Mortality | 4 (869) | RCT/High | Consistent Direct | Imprecise None detected | RR 1.57 (0.76 to 3.26) | Insufficient
VTE Events | 8 (1528) | RCT/Moderate | Inconsistent Indirect | Imprecise None detected | IPCD alone: RR 1.39 (0.73 to 2.64) RD=23 more/1000 (16 fewer to 98 more) IPCD+LMWH: RR 0.27 (0.05-1.64) RD=44 fewer/1000 (57 fewer to 38 more) | Low
Any DVT | 10 (1716) | RCT/Moderate | Inconsistent Indirect | Precise None detected | IPCD alone: RR 1.27 (0.81 to 2.00) RD=5 more/1000 (4 fewer to 20 more) IPCD+LMWH: RR 0.28 (0.04 to 1.79) RD=14 fewer/1000 (19 fewer to 16 more) | Low
Major bleeding | 4 (772) | RCT/Moderate | Consistent Direct | Imprecise None detected | RR 0.33 (0.07 to 1.51) RD=25 fewer/1000 (34 fewer to 19 more) | Low
KQ 2: IPCDs vs Anticoagulation in Medical Patients
Mortality | 1 (442) | RCT/High | Consistent Direct | Imprecise None detected | No events | Insufficient
VTE Events | 1 (442) | RCT/High | Consistent Indirect | Imprecise None detected | More events with IPCD (7 vs 2) but p=NS | Insufficient
Any DVT | 2 (679) | RCT/High | Consistent Indirect | Imprecise None detected | More events with IPCD (14 vs 6) but p=NS | Insufficient
Major bleeding | 1 (442) | RCT/High | Consistent Direct | Imprecise None detected | Equal number of events | Insufficient
KQ 3: Direct Comparisons of IPCDs in Surgical and Medical Patients
Mortality | 1 (423) | RCT/Moderate | Consistent Direct | Imprecise None detected | 1 death | Insufficient
VTE Events | 1 (423) | RCT/Moderate | Consistent Indirect | Imprecise None detected | Fewer VTE events with VenaFlow vs Kendall SCD^*^ | Low
VTE Events | 2 (143) | RCT/High | Consistent Indirect | Imprecise None detected | No difference between Kendall SCD and PlexiPulse | Insufficient
Any DVT | 1 (423) | RCT/Moderate | Consistent Indirect | Imprecise None detected | Fewer VTE events with VenaFlow vs Kendall SCD^*^ | Low
Any DVT | 2 (143) | RCT/High | Consistent Indirect | Imprecise None detected | No difference between Kendall SCD and PlexiPulse | Insufficient
Major bleeding | None | NA | NA | NA | NA | Insufficient

* Risk differences (RDs) were calculated for outcomes with pooled estimates of effect and strength of evidence ratings of low or higher.

Abbreviations: CI=confidence interval; DVT=deep vein thrombosis; IPCD(s)=intermittent pneumatic compression device(s); KQ=key question; LMWH=low molecular weight heparin; NA=not applicable; No.=Number; NS=not statistically significant; RCT=randomized controlled trial; RD=risk difference; RR= risk ratio; SCD=sequential compression device; VTE=venous thromboembolism

## SUMMARY OF EVIDENCE BY KEY QUESTION (KQ)

### KQ 1 IPCDs versus Anticoagulation in Surgical Patients

The majority of these studies were performed in patients undergoing joint replacement, with one study in other surgical populations. The A-V Impulse System foot device and the portable ActiveCare CECT devices were the IPCDs most commonly compared to anticoagulation. There was no difference between IPCDs and anticoagulation for the outcomes of VTE events, DVT events, and mortality, but confidence intervals were wide and did not exclude clinically important differences for some of these outcomes. There was also no clear pattern of differences in the studied outcomes by type or location of IPCD (foot, calf, thigh), surgical indication (TKA vs THA), or IPCD only versus combined therapy (IPCD plus anticoagulation), although some evidence suggests that combination of IPCD plus anticoagulation may be more effective than IPCD alone. IPCDs compared to anticoagulation may lower the risk of major bleeding.

### KQ 2 IPCDs versus Anticoagulation in Medical Patients

There are few studies examining IPCD performance for VTE prophylaxis in high-risk medical patients. We identified studies only in stroke and trauma patients, and calf IPCDs were the most commonly studied devices in these patients. Although there is limited evidence suggesting similar incidence rates of VTE events (DVT or PE) with IPCDs and anticoagulation, we judged the strength of evidence to be insufficient because of important risk of bias and wide confidence intervals that do not exclude clinically important differences in treatment effects.

### KQ 3 Direct Comparison of IPCDs in Surgical and Medical Patients

There are few studies that directly compare IPCDs for VTE prophylaxis in surgical patients, and none meeting our inclusion criteria in medical patients. One large study (moderate risk of bias) in TKA patients found evidence that a rapid inflation calf device (VenaFlow) was associated with lower VTE risk compared to a gradual inflation calf device (Kendall SCD). Two other studies in pelvic fracture and spinal surgery patients, comparing rapid inflation foot or foot-calf devices (PlexiPlus) to gradual inflation thigh-high devices (Kendall SCD), did not show significant differences in VTE event rates. No VTE-related mortality or major VTE-related complications were reported in any of these studies. With few studies reporting on the direct comparison of IPCDs, and indirect comparisons infeasible due to variability in study designs, we considered the strength of evidence to be insufficient to low.

### KQ 4 Ease of Use and Adherence in Surgical and Medical Patients

We examined RCTs and observational studies that compared IPCDs and reported data on ease of use or adherence in surgical and medical patients. One small RCT found greater adherence with use of a portable calf device (WizAir DVT CECT) compared to a non-portable calf device (Kendall SCD). Another RCT found no difference in adherence between a rapid inflation foot device (PlexiPlus) compared to a calf-thigh gradual inflation device (Kendall SCD). Observational studies found that foot devices had greater adherence compared to other IPCDs. However, observational studies had important methodological limitations. Overall, there were no consistent associations between specific brand-name IPCDs or sleeve location and ease of use or adherence.

## CLINICAL AND POLICY IMPLICATIONS

The prevalence of total joint replacements in the United States is increasing rapidly. By 2030, it is projected that the number of primary THAs in the United States will grow 174% to 572,000, and primary TKAs by 673% to 3.48 million procedures per year.64 Similar growth in these procedures is likely in the VA Health System since it serves an older population with a high prevalence of orthopedic conditions. However, appropriate prophylaxis is suboptimal in this high-risk population, and there is a growing gap between consensus guidelines and clinical practice.65-67 Among medically ill hospitalized Veterans, missed opportunities for VTE prophylaxis are also frequent and often include inappropriate mechanical prophylaxis or inadequate use of anticoagulation.68

Suboptimal utilization of mechanical prophylaxis with IPCDs is a patient safety issue that has significant cost implications for health systems. Therefore, there is health system interest in improving the quality of mechanical VTE prophylaxis prescribing to ensure that all surgical and medically ill hospitalized patients receive the most appropriate, safe, and cost-effective VTE prophylaxis possible. In the next section, we summarize recommendations from the 2 major U.S. clinical guideline panels that have addressed this issue and then provide a framework for selecting IPCDs in the face of uncertain evidence.

### Clinical Practice Guidelines

#### Surgical Patients

Both the American Academy of Orthopaedic Surgeons and the American College of Chest Physicians (ACCP) have recently issued guidelines on thromboprophylaxis.14-16 Recommendations for thromboprophylaxis are related to the surgery, the risk of bleeding, and the risk of VTE. IPCD prophylaxis is recommended for orthopedic and non-orthopedic patients at high risk of bleeding. For non-orthopedic procedures in patients at low risk of bleeding, IPCD prophylaxis is recommended for patients who are also at low risk of VTE. For orthopedic procedures, portable battery-powered IPCDs and devices capable of recording wear time are recommended as an option for patients at low risk of bleeding, but pharmacological prophylaxis with or without IPCD is preferred.16 Overall, however, these clinical guidelines do not recommend for or against specific IPCDs for VTE prophylaxis and were based on low-quality evidence. Relevant to these guidelines are our findings that IPCDs, compared to anticoagulation, may have decreased risk of major bleeding complications, and that the combination of IPCD and anticoagulation may be more effective at preventing VTE than anticoagulation alone.

#### Medical Patients

According to the 2012 ACCP guidelines, optimal use of mechanical thromboprophylaxis with IPCDs is recommended in acutely ill medical inpatients at increased risk for thrombosis, who are bleeding, or who are at high risk for major bleeding.13 These are consensus-based recommendations. The VA patient population has more medical conditions than the general patient population,69 placing our patients at high risk for VTE and bleeding complications. Given the limited data on mechanical IPCD use in high-risk medical patients, we judged the strength of evidence to be insufficient to determine the effects on clinically important outcomes in this population.

## FRAMEWORK FOR SELECTING IPC DEVICES

Making clinical and policy recommendations in the face of uncertain evidence is challenging. Our review was structured to consider 3 types of evidence: 1) head-to-head comparisons of IPCDs; 2) indirect comparisons of IPCDs to a common comparator (eg, foot vs calf devices, each compared to anticoagulation); and 3) data on ease of use or adherence from patients or staff. An additional type of evidence is simply the frequency with which particular devices or device types have been evaluated.

Although there are mechanistic differences between ICPDs, such as sleeve location (foot, calf, thigh) and inflation and compression cycle patterns, as well as conceptual differences, such as device portability, we did not find definitive evidence to suggest that any of these factors are associated with clinically important differences in VTE rates or patient- or staff-rated ease of use. When the strength of evidence from published studies is insufficient for confident decision making, other criteria may be applied. In 2007, the Emergency Care Research Institute (ECRI Institute) evaluated selected IPCDs and proposed the following evaluation criteria: safety features, patient comfort, performance (eg, inflate to specified pressure), quality of construction, battery life and other battery related features (if battery equipped), and ease of setup and other ease-of-use features.70 In addition, the guideline-recommended use of portable, battery-powered IPCDs with hour meters in joint replacement patients16 may be applicable to other surgical and medical populations, but further study of this is needed. Additional considerations are costs and flexibility. If a single device can be used in a variety of modes and with a variety of compression bladders, then that device may serve a broader range of clinical needs. An updated evaluation that describes these features for devices currently on the market could inform decision making.

## LIMITATIONS

Limitations can be categorized broadly into those related to the methods of the review and those related to the included studies. Our review differs from prior reviews in important ways. We limited eligibility to studies reporting VTE outcomes at 4 weeks or greater, a period of clinically important elevated risk for VTE. By excluding short-duration studies, we prioritized the most clinically relevant time-point, but excluded trials that may have contributed some useful data. We also imposed geographical limits to restrict the review to medical systems most similar to the United States, but this led to exclusion of at least 2 trials that would otherwise have been eligible.71,72 A sensitivity analysis (data not shown) that included these studies for the outcomes “any DVT” and “major bleeding” had no important effect on the estimates of effect. In other ways, our eligibility criteria were more expansive. We included surgical and medical populations at elevated risk of VTE and observational studies to better evaluate ease-of-use outcomes. We also conducted novel subgroup analyses by device characteristics to explore whether these characteristics could guide policymakers or health systems in device selection. The devices studied may, however, not be the same as those currently on the market; furthermore, in some instances, we do not know all the features of the devices studied. Our search of ClinicalTrials.gov did not identify any completed but unpublished studies, but statistical methods to evaluate publication bias were limited due to the relatively small number of studies.

The chief limitations of the literature were the paucity of head-to-head comparisons of IPCDs and the focus on DVT assessed by screening imaging studies, resulting primarily in the identification of asymptomatic DVTs of uncertain clinical importance. Other limitations include important methodological limitations in both RCTs and observational studies. However, sensitivity analyses did not show important differences in pooled estimates when studies at high risk of bias were excluded. We also found important heterogeneity in treatment effects for VTE and DVT outcomes, heterogeneity that was only partly explained by subgroup analyses. This unexplained heterogeneity decreased our confidence in the strength of evidence. Finally, changes in manufacturers over time made it difficult to identify some devices and their characteristics accurately.

Despite these limitations, men and women were well-represented in the included studies, and the median average age was 54 years, somewhat younger than the average patient admitted to VA hospitals. Other than age, which is associated with risk for VTE, these results should be applicable to VA patients and VA hospitals.

## RESEARCH GAPS/FUTURE RESEARCH

We used the framework recommended by Robinson et al73 to identify gaps in evidence and prioritize future needs (Table 4). This approach considers PICOTS (population, intervention, comparator, outcomes, timing, and setting) to identify gaps.

Table 4 Evidence Gaps and Future Research Needs

Evidence Gap | Reason | Type of Studies to Consider
Patients
Effects of IPCDs in medically ill patients | Insufficient information | RCTs or multi-site observational studies
Effects of IPCDs in non-orthopedic high-risk surgical groups (bariatrics, gynecological, or robotic surgeries) | Insufficient information | Large RCTs or multi-site observational studies
Interventions
Optimal IPCD type or category | Insufficient information | RCTs or quasi-experimental studies of head-to-head comparisons of IPCD sleeve locations, compression patterns, and inflation times
Comparator
Effectiveness of IPCDs compared to newer oral anticoagulants | Insufficient information | RCTs or observational studies
Outcomes
Accuracy of treatment effects beyond 4 weeks | Insufficient information | Trials with more careful assessment of VTE rates at 1 month and beyond, outcomes assessed blinded to treatment assignment
Effects on clinically relevant outcomes | Insufficient information | Trials with proximal and symptomatic DVT outcome assessments, trials with standard approaches to assessing/reporting bleeding
Effects on adherence and patient/staff tolerability | Insufficient information | Trials using standard, validated questionnaires for patient/staff assessment of ease of use outcomes

Abbreviations: DVT=deep vein thrombosis; IPCD(s)=intermittent pneumatic compression device(s); RCTs=randomized controlled trials; VTE=venous thromboembolism

## CONCLUSIONS

Although IPCDs differ in practical features and in effects on physiology, current evidence does not show a clear difference in effects on clinically important outcomes. As a strategy for thromboprophylaxis, we found that IPCDs may decrease the risk of major bleeding compared to anticoagulation, and when used in combination with LMWH, may decrease the risk of VTE. We conclude that IPCDs are a viable option for VTE thromboprophylaxis when used in accordance with current clinical guidelines. When choosing a specific IPCD, focusing on device flexibility, acceptability by nursing staff and patients, and the most frequently studied devices, as well as on cost, can help direct selection of appropriate IPCDs. Comparative effectiveness studies are urgently needed to address current gaps in evidence.