# RESULTS

## LITERATURE FLOW

Our literature search (Figure 1) identified 1461 unique citations from a combined search of MEDLINE (n=959), Embase (n=393), CINAHL (n=15), Cochrane CENTRAL (n=84), and the bibliographies of included studies and review articles (n=10). After applying inclusion/exclusion criteria at the title-and-abstract screening level, 171 full texts were retrieved for further review. Of these, 21 unique studies (18 RCTs and 3 observational studies) were retained for data abstraction and grouped by key question (KQ).

Figure 1 Literature Flow Chart

* Two studies applied to both KQ 3 and KQ 4.

Abbreviations: KQ=key question; n=number of studies.

We attempted to contact 14 authors for additional study information; 5 could not be reached, and only 6 others supplied the requested data. A search of ClinicalTrials.gov to ascertain publication bias revealed no additional or completed but unpublished trials.

Eighteen RCTs (3666 subjects), conducted primarily in patients undergoing joint replacement surgery, compared the effectiveness of intermittent pneumatic compression devices (IPCDs) to anticoagulation (n=14) or other IPCDs (n=7) (Figure 2).

Figure 2 Numbers of Comparisons between Interventions (RCTs only, n=18)

Abbreviations: IPCD=intermittent pneumatic compression device; LMWH=low molecular weight heparin; UFH=unfractionated heparin

There were no RCTs comparing antiplatelet agents to IPCDs. Four RCTs and the 3 observational studies (1040 subjects) reported on adherence or ease of use (KQ 4). Devices from 7 different manufacturers were represented (Table 2); however, the brand name of the device and the name of the manufacturer were not always provided. The most commonly studied named devices were the Kendall SCD™ (7 studies) and the Novamedix A-V Impulse System™ (5 studies). Study characteristics are described in greater detail in Appendix D. Further characteristics of the devices are provided in Appendix E.

Table 2 Devices Evaluated in Included Studies

Manufacturer^*^ | Device Name^†^ | Device Characteristics;^‡^ Sleeve Location(s)^§^ | Number of Studies
Kendall | Kendall SCD™ | Multi-chamber, sequential compression, slow inflation, portable and non-portable options available, no hour meter Sleeve location(s) available: Foot, calf, calf-thigh | 7 studies: Lachiewicz, 2004^46^ Murakami, 2003^23^ Pagella 2007^47^ Robertson, 2000^48^ Rokito, 1996^49^ Stannard, 2001^50^ Wood, 1997^51^
Novamedix | A-V Impulse System™ | Single chamber, constant pressure, rapid inflation, non-portable, hour meter Sleeve location(s) available: Foot | 5 studies: Blanchard, 1999^52^ Pitto, 2004^18^ Warwick, 2002^19^ Warwick, 1998^53^ Windisch,2011^54^
Huntleigh | Flowtron^®^ | Single chamber, constant compression, slow inflation, portable and non-portable options available, no hour meter Sleeve location(s) available: Foot, calf, calf-thigh | 3 studies: Ginzburg, 2003^55^ Pagella, 2007^47^ Stone, 1996^56^
NuTech | PlexiPulse^®^ | Multi-chamber, constant compression, rapid inflation, non-portable, hour meter (1 study) and no hour meter (2 studies) Sleeve location(s) available: Foot, calf, foot-calf | 3 studies: Robertson, 2000^48^ Stannard, 2001^50^ Wood, 1997^51^
Aircast | VenaFlow^®^ | Multi-chamber, sequential compression, rapid inflation, non-portable, hour meter Sleeve location(s) available: Foot, calf, calf-thigh | 2 studies: Lachiewicz, 2004^46^ Silbersack, 2004^57^
Medical Compression Systems (MCS) | ActiveCare DVT^®^ | Multi-chamber, sequential compression, slow inflation, portable CECT, hour meter Sleeve location(s) available: Foot, calf, calf-thigh | 1 study: Edwards, 2008^58^
Medical Compression Systems (MCS) | ActiveCare+S.F.T.^®^ | Multi-chamber, sequential compression, slow inflation, portable CECT, hour meter Sleeve location(s) available: Foot, calf, calf-thigh | 1 study: Colwell, 2010^17^
Medical Compression Systems (MCS) | WizAir DVT™ CECT | Multi-chamber, sequential compression, slow inflation, portable CECT, hour meter Sleeve location(s) available: Calf | 1 study: Murakami, 2003^23^
Jobst | Anthrombic Pump (System 2500)║ | Multi-chamber, sequential compression, slow inflation, non-portable, no hour meter Sleeve location(s) available: Calf, calf-thigh | 1 study: Pambianco, 1995^59^
Unnamed | Unnamed | – | 3 studies (8 devices): Bockheim, 2009^60^ Greenfield, 1997^61^ Proctor, 2001^62^

* Manufacturers of the various IPCDs have changed over time. We report the manufacturer at the time of the study, as accurately as we were able to ascertain this.

† Device names are given as reported in the study, sometimes revised/augmented to reflect trademarked device names at the time of the study, as accurately as we were able to ascertain these.

‡ Device characteristics are given as reported in the study, sometimes augmented to reflect the characteristics of trademarked devices at the time of the study, as accurately as we were able to ascertain these. Device characteristics may have changed over time. In particular, some devices that were non-portable at the time of the included studies may now be available in a portable form. Where more than one option was available for a given device characteristic (eg, portable and non-portable, hour meter and no hour meter), the option(s) listed in bold font were used in the included studies.

§ Sleeve locations in bold font were used in the included studies.

║ Specific information on this device was not provided in the published study report, but rather by Huntleigh, the company that most recently bought out Jobst. They sent us a copy of the manual for the specific Jobst model used in the Pambianco, 1995 study.59

Abbreviations: CECT=continuous enhanced circulation therapy device; DVT=deep vein thrombosis; SCD=sequential compression device; S.F.T.=Synchronized Flow Technology

As Table 2 indicates, the IPCDs evaluated in the included studies primarily used foot or calf sleeves. The mean age of patient samples ranged from 39.5 to 73 years old (median 53.7 years). On average, 47% (range, 24% to 91%) of samples were men. In 16 trials evaluating DVT, routine imaging (typically with ultrasound, 75% of studies) at 3 to 8 days was used for diagnosis, while evaluation for PE was normally triggered by symptoms and was diagnosed by ventilation/perfusion (V/Q) scan or computed tomography in only 44% of studies. Post-hospitalization VTE was diagnosed by history, sometimes supplemented with medical records. Approximately 95% of VTE events were due to DVT. In the 13 studies reporting the distribution of DVT, 18.5% were proximal and 81.5% were distal. Most studies reported the combined rate of symptomatic and asymptomatic DVT, but when reported separately, only 3.2% of DVTs were symptomatic. Only 7 studies reported major bleeding, 5 of which17,18,52,55,56 conformed to the International Society on Thrombosis and Haemostasis (ISTH) definition.63 Studies were rated moderate (n=14) or high (n=7) risk of bias (Appendix B).

## KEY QUESTION 1 In hospitalized surgical patients at high risk for venous thromboembolism (VTE), what is the comparative effectiveness of VTE prophylaxis with intermittent pneumatic compression devices versus VTE prophylaxis with pharmacologic agents for VTE events, VTE-related mortality, and adverse events?

### Description of Included Studies

Ten RCTs (1905 patients) evaluated IPCDs versus anticoagulation for VTE prophylaxis. Seven studies compared IPCDs alone versus anticoagulation,17-19,49,52,53,56 while 3 studies compared an IPCD in combination with anticoagulation versus anticoagulation alone.54,57,58 IPCDs were primarily evaluated in joint replacement patients. Only one study evaluated IPCDs in spinal surgery patients. The remaining 9 studies were conducted on patients undergoing total knee arthroplasty (TKA; 3 studies) or total hip arthroplasty (THA; 4 studies); 2 studies combined patient populations undergoing TKA and THA. One of the latter58 reported results separately for TKA and THA, resulting in a total of 11 comparisons.

The following types of IPCDs were evaluated: foot devices (5 studies), calf devices (4 studies), and a calf-thigh device (1 study). All 10 studies reported the brand name of the devices studied; these were the A-V Impulse System™ foot device (5 studies), the ActiveCare^®^ portable continuous enhanced circulation therapy (CECT) calf device (2 studies, possibly 2 slightly different models), the VenaFlow^®^ rapid-inflation calf device (1 study), the Flowtron^®^ calf device (1 study), and the Kendall SCD™ calf-thigh device (1 study). Foot devices used rapid inflation modes, while all but one calf devices used gradual inflation modes. Devices were typically started intra-operatively or immediately post-operatively, and duration of use ranged from 5 to 12 days or until hospital discharge. Anticoagulation included the LMWHs enoxaparin (7 studies) and nadroparin (2 studies), and the vitamin K antagonist warfarin (1 study). The duration of anticoagulation was less than 10 days in all included studies except for one, which reported use of 30 days or less.57 Patients excluded from the trials were primarily those with a high risk of bleeding, a prior history of VTE, a history of malignancy, revision of surgery, or painful joints precluding the use of the foot device.

The risk of bias was judged to be moderate in 8 studies17-19,49,53,54,56,57 and high in 2 studies.52,58 Appendix B provides details of the quality ratings for each study.

### Outcomes

Outcomes included VTE events (DVT and/or PE), any DVT (symptomatic or asymptomatic), symptomatic DVT, PE, all-cause mortality, and major bleeding adverse events. The duration of follow-up for all VTE outcomes and mortality was from 4 weeks to 1 year. We report VTE outcomes separately for joint replacement surgical patients and other surgical patients. Subgroup analyses were feasible only for VTE and DVT outcomes in studies of joint replacement. Additionally, we qualitatively synthesized data on IPCD adherence.

#### VTE Outcomes in Surgical Joint Replacement Patients

##### VTE Events (DVT and/or PE)

Among patients undergoing joint replacement surgery, VTE events were identified in 163 patients (11%). VTE events were more common in TKA patients (20%) than in THA patients (8%). Eight of the 10 RCTs in our sample examined the role of IPCDs alone (4 studies) or IPCDs used in combination with anticoagulation (4 studies) in preventing VTE events. One study reported results separately for TKA and THA patients, resulting in 9 comparisons for this analysis. In patients who underwent THA or TKA, there was no statistically significant difference between IPCDs and anticoagulation for VTE events (RR 0.80; 95% confidence interval [CI], 0.35 to 1.78; Figure 3), but intervention effects varied substantially across studies (Q=23.4; p=0.003; I^2=^66%). A sensitivity analysis restricted to studies at moderate risk of bias did not change the pooled estimate substantially (RR 0.78; 95% CI, 0.25 to 2.38). As noted above, the pooled estimate for this outcome was highly heterogeneous. Subgroup analyses separately evaluating IPCDs alone versus anticoagulation (RR 1.39; 95% CI, 0.73 to 2.64; I^2^=37%) and IPCDs plus anticoagulation versus anticoagulation alone (RR 0.27; 95% CI, 0.05 to 1.64; I^2^=16%) suggested that the combination of IPCDs plus anticoagulation may provide a large protective effect against VTE events, but the confidence interval included the possibility of a chance association (Figure 3).

Figure 3 Risk for VTE Events with IPCD versus Anticoagulation Prophylaxis in Joint Replacement Patients

Subgroup analysis of gradual versus rapid inflation devices showed consistent effects for gradual inflation devices (RR 0.61; 95% CI, 0.24 to 1.56; I^2^=0%), but inconsistent effects for rapid inflation devices (RR 0.80; 95% CI, 0.35 to 1.78; I^2^=71%). We examined outliers qualitatively. Two small studies differed substantially from the pooled estimate. One study at high risk of bias52 found increased risk of VTE events in TKA patients with an AV Impulse foot device compared to LMWH (RR 2.26; 95% CI, 1.39 to 3.67). In contrast, a study by Silbersack and colleagues,57 judged to be at moderate risk of bias, found a protective effect against VTE events in a combined population of TKA and THA patients using a VenaFlow rapid inflation calf device plus LMWH versus LMWH alone (RR 0.03; 95% CI, 0.00 to 0.41).

##### Any DVT Events (Symptomatic or Asymptomatic)

Ten RCTs examined IPCDs alone (6 studies) or IPCDs plus anticoagulation (4 studies) versus anticoagulation alone and reported any DVT events. A total of 264 DVT events (15%) were identified; most DVTs were distal (81%). Proximal DVTs were more common in THA patients (53%) than in TKA patients (7%). There was no important difference in the risk of any DVT event between IPCDs and anticoagulation (RR 0.93; 95% CI, 0.51 to 1.71; Figure 4), but intervention effects varied substantially across studies (Q=23.0; p=0.006; I^2=^ 61%). A sensitivity analysis restricted to studies at moderate risk of bias did not change the pooled estimate substantially (RR 0.97; 95% CI, 0.53 to 1.78). Subgroup analyses separately evaluating IPCDs alone versus anticoagulation (RR 1.27; 95% CI, 0.81 to 2.00; I^2^=46%) and IPCDs plus anticoagulation versus anticoagulation alone (RR 0.28; 95% CI, 0.04 to 1.79; I^2^=18%) suggested that the combination of IPCDs plus anticoagulation may provide a large protective effect against VTE events, but the confidence interval included the possibility of a chance association (Figure 4).

Figure 4 Risk for any DVT Events with IPCD versus Anticoagulation Prophylaxis in Joint Replacement Patients

Additional subgroup analyses explain some but not all variability. Subgroup analyses by surgical site showed that heterogeneity was primarily driven by TKA studies. Among the TKA studies, one small study at high risk of bias52 was different from others in this group. This study found that the AV Impulse System foot device compared to LMWH increased the risk for any DVT (RR 2.26; 95% CI, 1.39 to 3.67). In this study, both lower limbs, as opposed to only the ipsilateral surgical limb, were assessed for DVT. THA studies showed consistent treatment effects and no difference between IPCDs and anticoagulation for risk of DVT events (RR 1.08; 95% CI, 0.66 to 1.76; I^2^=0%). Because of the high correlation between device location and inflation mode, subgroup analyses by inflation mode yielded similar results to the analysis of calf versus foot location.

##### Symptomatic DVT

Although a clinically important outcome, few studies examined symptomatic DVT. Six RCTs (4 studies IPCD alone, 2 studies combination IPCD plus anticoagulation) reported symptomatic DVTs in TKA and THA patients. A total of 6 (0.5%) symptomatic DVTs were identified (n=1143), 3 each in THA and TKA patients. There was no statistically significant difference in symptomatic DVT events when an IPCD was used instead of or in addition to anticoagulation (RR 1.02; 95% CI, 0.48 to 2.14; I^2^=0%).

##### Pulmonary Embolism (PE)

Eight RCTs evaluated IPCDs versus anticoagulation for the prevention of PEs. A total of 7 PEs (0.4%) were identified (n=1596); 5 were in THA patients, and 2 in TKA patients. IPCDs, either alone (4 studies) or in combination with anticoagulation (4 studies), offered no advantage in reducing PE events compared to anticoagulation in THA or TKA patients (RR 1.11, 95% CI 0.83 to 1.49; I^2^=0%). We found consistent results, but analyses were limited by the small number of events.

#### VTE Outcomes in Other Surgical Patients

IPCDs were compared to anticoagulation in only one other surgical population. A small RCT (n=110)49 performed in spinal surgery patients compared a Kendall SCD calf-thigh device to warfarin and found no significant difference in treatment effect for outcomes of VTE events (DVT and/or PE), any DVT (symptomatic or asymptomatic), symptomatic DVT, or PE. The risk of bias was judged to be moderate.

#### Mortality

A subset of 4 RCT studies (869 patients) examined all-cause mortality in patients undergoing joint replacement; the length of follow-up ranged from 4 weeks to 3 months. Only one of the 4 RCTs reported any deaths (4 patients),19 finding no difference in mortality between the A-V Impulse System foot device and LMWH. The overall pooled effect estimate for the 4 RCTs found no difference in the risk of all-cause mortality between IPCDs and anticoagulation (RR 1.57; 95% CI, 0.76 to 3.26; I^2^=0%), but the confidence intervals were wide and did not exclude a clinically important difference.

#### Adverse Events

Adverse events were defined as clinically relevant major bleeding (defined using ISTH criteria for major bleeding in surgical patients), any bleeding, or skin or nerve damage. Meta-analysis was performed only for the outcome of major bleeding.

##### Major Bleeding

Six RCTs evaluated major bleeding outcomes, but only 4 of these used ISTH criteria for major bleeding in surgical patients (total n=791). Major bleeding was reported in 22 (3%) joint replacement patients (19 patients randomized to anticoagulation versus 3 patients randomized to IPCD). Meta-analysis of these 4 studies suggest that IPCDs may reduce the risk of major bleeding events compared with anticoagulation (RR 0.33; 95% CI, 0.07 to 1.51; I^2^=0%; Figure 5). The only individual study to find an IPCD protective against major bleeding events was conducted by Colwell et al,17 who studied 392 THA patients and compared a portable CECT calf device (ActiveCare+S.F.T.^®^) versus LMWH. Risk of bias was moderate. Patients in both treatment groups were allowed to receive 81 mg aspirin daily. Patients in the IPCD group had a RR of developing a major bleed of 0.04 (95% CI, 0.0 to 0.72) compared with those who received LMWH. This was also the largest of the studies examining major bleeding outcomes, suggesting that smaller trials may have been underpowered to detect major bleeding outcomes.

Figure 5 Risk for Major Bleeding Events with IPCD versus Anticoagulation Prophylaxis in Joint Replacement Patients

##### Any Bleeding

Any bleeding was reported in 3 RCTs of patients undergoing joint replacement and one study of patients undergoing spine surgery (total n=710). Bleeding was reported in 83 (23.3%) patients randomized to IPCD and in 105 (29.6%) patients randomized to anticoagulation.

##### Skin and Nerve Damage

Skin and nerve damage was assessed in 3 studies; however, no patients were identified with this injury.

#### IPCD Adherence

Adherence was described as rates of discontinuation and average duration of use per day of ICPDs. Four RCTs reported rates of discontinuation, all of which examined the A-V Impulse System foot device. This device was discontinued in 42 of 543 patients (8%). Average duration of use per day was examined in 6 RCTs, including the study by Edwards et al,58 which reported results separately for TKA and THA patients, resulting in 7 total comparisons. IPCDs were worn for an average of 14.5 hours per day (range 11 to 22). The ActiveCare portable CECT calf device was worn for an average of 20 hours per day (range 19 to 20), whereas the non-portable A-V Impulse System foot device was worn for an average of 16 hours per day (range 11 to 22).

## KEY QUESTION 2 In hospitalized medical patients at high risk for VTE, what is the comparative effectiveness of VTE prophylaxis with IPC devices versus VTE prophylaxis with pharmacological agents for VTE events, VTE-related mortality, and adverse events?

### Description of Included Studies

Three eligible RCTs (n=855) compared IPCDs to anticoagulation in high-risk medical inpatients.55,59,61 VTE prophylaxis was initiated within 24 to 48 hours post-admission in 2 studies;55,61 time to initiation was not specified in the other study.59 All 3 trials continued VTE prophylaxis until hospital discharge or for 4 weeks, the entire study duration. The first study (n=360) compared a calf IPCD (Jobst Anthrombic Pump) to standard dose LMWH in stroke patients with lower extremity weakness.59 The second study (n=442) compared a calf IPCD (Flowtron) to unfractionated heparin, dose-adjusted to a therapeutic partial thromboplastin time (PTT) level, in a high-risk, heterogeneous group of trauma patients.55 The third study was a small feasibility study (n=53) that compared 4 study arms, 2 different IPCDs (calf compression devices and arteriovenous foot devices, manufacturers not specified) and 2 forms of heparin prophylaxis (unfractionated and LMWH) in a high-risk trauma sample.61 Although this trial met eligibility criteria, it did not report outcomes separately for each study arm, precluding valid interpretation of results.

The risk of bias was judged to be moderate for 2 trials,55,59 mainly because of higher rates of attrition in the IPCD group and exclusion of these patients from analyses,59 and because participants were excluded due to non-compliance with the assigned intervention.55 The third study61 was judged to be at high risk of bias because of lack of clarity on key methodological criteria. Appendix B provides details of the quality ratings for each study. No eligible study examined other populations of interest with an elevated risk of thromboembolic complications, such as medical intensive care unit patients or patients with malignancy.

### VTE Outcomes

#### VTE Events (DVT and/or PE)

Two trials did not find a statistically significant difference in DVT incidence between IPCD and heparin treatment groups. For stroke patients, the incidence of proximal DVT events was 6.8% versus 4.2% with IPCDs versus heparin, respectively.59 For trauma patients, the overall incidence of DVT events (proximal and distal) was 2.7% versus 0.5% with IPCDs versus heparin, respectively.55 Neither study indicated whether DVT events diagnosed by ultrasound were symptomatic or asymptomatic, which limits the clinical usefulness of these results. Only one of the 2 trials reported PE events.55 The incidence of PE events was similar: one event in the IPCD group compared to one in the heparin treatment group.

#### Mortality

Only one of the 2 trials reported mortality.55 There were no deaths in this study.

### Adverse Events

Only one study reported the rate of any bleeding or major bleeding.55 The incidence of bleeding did not differ significantly between the dose-adjusted heparin group (5.0%) and the IPCD group (3.6%; p=0.237). The incidence of major bleeding events was identical (1.8%) in the 2 study groups.

## KEY QUESTION 3 In hospitalized surgical and medical patients at high risk for VTE, what is the comparative effectiveness of different IPC devices when compared to one another for preventing VTE events?

### Description of Included Studies

Three RCTs (666 patients) directly compared 2 different IPCDs.46,50,51 Devices from 3 manufacturers, including those using foot, calf, and thigh sleeves, were compared in surgical populations undergoing joint replacement, spinal surgery, or repair of a traumatic acetabular or pelvic fracture. VTE prophylaxis was initiated intraoperatively46,51 or shortly following admission.50 Only one study specified treatment duration,51 continuing the IPCD until the day of discharge. Risk of bias was moderate in 2 studies46,50 and high in the third.51 In 2 studies, outcome assessors were not blinded to the type of IPCD.46,51 Baseline risk profiles in the 2 randomized groups were not comparable in one study.51

### VTE Outcomes

#### VTE Events (DVT and/or PE)

A large study (moderate risk of bias) randomized 423 patients undergoing TKA to a calf rapid inflation asymmetrical compression (RIAC) device (VenaFlow) or to a calf sequential compression device (SCD) (Kendall SCD).46 The rate of VTE events was significantly lower in the Venaflow arm than in the Kendall SCD arm (6.9% vs 15%, respectively; p=0.007); all but one VTE events were DVTs, and it was not specified whether the DVTs were symptomatic. The study authors concluded that thromboprophylaxis using VenaFlow was associated with a significantly lower risk of VTE compared to the Kendall SCD.

Two studies compared a slow-gradual inflation SCD (Kendall SCD) to rapid inflation devices (PlexiPulse).50,51 In a study of 107 patients undergoing pelvic fracture surgery (moderate risk of bias), the overall rate of VTE events was 14%; all but one VTE events were DVTs, and it was not specified whether the DVTs were symptomatic.50 Patients received either a calf-thigh SCD (Kendall SCD) or a combination calf and foot rapid inflation device(PlexiPulse). The rate of VTE events in the Kendall SCD arm was not significantly different from that in the PlexiPulse arm (10 [19%] vs 5 [10%]; p=0.265). In another study (high risk of bias), 136 patients undergoing spinal surgery were randomized to receive either a calf-thigh SCD (Kendall SCD) or a sequential rapid inflation foot device (PlexiPulse).51 No patients randomized to the Kendall SCD were diagnosed with a VTE compared to 2 patients in the PlexiPulse arm (1 DVT and 1 PE).

#### Mortality

One study reported one death (0.2%) due to myocardial infarction, but no VTE-related mortality.46 The other studies did not report mortality outcomes.

### Adverse Events

None of the included studies reported major bleeding events as an outcome. In one study, 36 patients (26%) complained of redness, itching, or discomfort associated with IPCDs.51 Of these, 18 (24%) were using the PlexiPulse system and 18 (31%) were using the Kendall SCD (p>0.5). In the TKA study,46 one patient with pigmented synovitis required post-operative aspiration.

## KEY QUESTION 4 When used for VTE prophylaxis, do different IPC devices differ in ease of use or adherence?

### Description of Included Studies

Four RCTs (374 patients)23,47,50,51 and 3 observational studies (1724 patients)48,60,62 compared different IPCDs to one another and reported data on ease of use or adherence. All but one study were conducted in surgical populations. At least 5 devices were included, and specific device names were reported (or obtained through correspondence with study authors) for all but 2 studies.60,62 Studies were judged to be at moderate (n=3)23,47,50 or high (n=4)48,51,60,62 risk of bias. Important limitations in the 3 observational studies were: sequential rather than contemporaneous comparisons of devices; analyses that did not adjust for potential confounders; and use of unvalidated measures to assess comfort or ease of use.

### Ease of Use

Four studies reported patient-rated comfort and 2 reported staff-rated ease of use. A PlexiPulse rapid inflation foot device was compared to a Kendall SCD calf-thigh device in 2 studies, one moderate-sized RCT finding no difference in comfort ratings,51 and a larger observational study finding the PlexiPulse device rated more favorably.48 Another small RCT compared the Kendall SCD calf and Flowtron calf devices.47 Patients rated the Flowtron breathable sleeve more comfortable than the Kendall SCD thick stiff plastic sleeve on 1 of 6 items. Staff rated the Flowtron device easier to use (by approximately 1 point on a 5-point Likert Scale) on each of 6 different items. An observational study comparing 5 manufacturers with multiple different sleeves found differences in patient-rated comfort and staff-rated ease of use, but the device-sleeve combinations were not described in a manner that would allow the preferred devices or device type to be identified.62

### Adherence

Six studies compared adherence for 2 or more IPCDs as reported by patients, staff observation, or counters installed on the devices. There were no consistent associations between specific named devices or location of the sleeve and adherence. Two observational studies found greater adherence with a foot device compared to other IPCDs.48,60 A small RCT found greater adherence with the portable WizAir DVT CECT calf device (77.7%), which includes a battery pack, compared to a Kendall SCD calf device (58.9%).23 Other studies found no important differences between a Kendall SCD using a thick plastic sleeve and a Flowtron device using a breathable plastic sleeve,47 did not identify the devices evaluated,62 or did not perform statistical analyses because of missing data.50

In KQ 1, we reported adherence in studies comparing an IPCD to anticoagulation. These studies also found longer use with a portable device (mean of 20 hours) compared to the A-V Impulse System foot device, a non-portable device.