# METHODS

## TOPIC DEVELOPMENT

The topic was nominated after a process that included a preliminary review of published peer-reviewed literature and consultation with investigators, Veterans Affairs (VA) and non-VA experts, and key stakeholders (VA National Surgery Office, VA Office of Nursing). The VA Sequential Pressure Device Evaluation Committee nominated this project. The committee is interested in developing policy about the use of intermittent pneumatic compression devices (IPCDs), and specifically was interested in an evaluation to determine the comparative effectiveness of IPCDs.

We followed a standard protocol for this review, and each step was pilot tested to train and calibrate study investigators. The PROSPERO registration number is CRD42014015157. The final key questions (KQs), developed in consultation with stakeholders, are:

- KQ 1: In hospitalized surgical patients at high risk for venous thromboembolism (VTE), what is the comparative effectiveness of VTE prophylaxis with IPCDs versus VTE prophylaxis with pharmacological agents for VTE events, VTE-related mortality, and adverse events?
  a. Does effectiveness vary by surgical procedure?
  b. Does effectiveness vary by type of IPCD?
- KQ 2: In hospitalized medical patients at high risk for VTE, what is the comparative effectiveness of VTE prophylaxis with IPCDs versus VTE prophylaxis with pharmacological agents for VTE events, VTE-related mortality, and adverse events?
  a. Does effectiveness vary by medical condition?
  b. Does effectiveness vary by type of IPCD?
- KQ 3: In hospitalized surgical and medical patients at high risk for VTE, what is the comparative effectiveness of different IPCDs when compared to one another for preventing VTE events?
- KQ 4: When used for VTE prophylaxis, do different IPCDs differ in ease of use or adherence?

## SEARCH STRATEGY

In consultation with an expert librarian, we searched MEDLINE (via PubMed), Embase, CINAHL, and Cochrane CENTRAL from January 1, 1995, to October 30, 2014, for peer-reviewed, English-language randomized controlled trials (RCTs). We used Medical Subject Heading (MeSH) terms and selected free-text terms for IPCDs and the conditions of interest, along with validated search terms for RCTs.33 For KQ 4, we also used terms to identify relevant observational studies. The exact search strategies used are provided in Appendix A. We further reviewed the bibliographies of included trials and systematic reviews20-22,30,34-40 for missed publications.

To assess for possible publication bias, we searched ClinicalTrials.gov (www.clinicaltrials.gov) to identify completed but unpublished studies meeting our eligibility criteria.

All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X5, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using pre-specified inclusion and exclusion criteria, 2 trained investigators assessed titles and abstracts for relevance to the KQs. Full-text articles identified by either investigator as potentially relevant were retrieved for further review and examined by 2 investigators against the eligibility criteria. Disagreements on inclusion, exclusion, or the major reason for exclusion were resolved by discussion or by a third investigator. The criteria to screen articles for inclusion or exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 1. In addition, trials with 3 or more arms were examined for appropriateness of all arms for inclusion. For example, data from any active arm that did not include an IPCD or eligible anticoagulant were not abstracted for inclusion in the analysis.

Table 1 Inclusion and Exclusion Criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adults 18 years or older hospitalized for THA, TKA, hip fracture surgery, back surgery, bariatric surgery with surgical duration >1 hour, robotic-assisted prostatectomy, or robotic-assisted hysterectomy (KQ 1, KQ 3, KQ 4); and hospitalized medical patients with active malignancy, stroke, trauma, critical illness, or high risk of VTE determined by a validated risk model (KQ 2, KQ 3, KQ 4) | Low risk of VTE Mixed samples with fewer than 70% meeting eligibility criteria
Intervention | IPCD used for ≥24 hours, with or without pharmacological prophylaxis | Graduated compression stockings Devices that stimulate venous flow through ankle flexion and extension
Comparator | KQ 1 and KQ 2: Pharmacological prophylaxis with LMWH, FXa inhibitors, direct thrombin inhibitors, adjusted-dose vitamin K antagonists, fondaparinux, or aspirin KQ 3 and KQ 4: An IPCD | Placebo, antiplatelet drugs other than aspirin, graduated compression stockings, electrical calf stimulation devices, foot flexion/extension devices Any comparator where the effect of the electronic aspect of the intervention could not be isolated
Outcome | Studies must report effects on at least one of the following relevant outcomes: KQ 1 and KQ 2: VTE events (DVT and/or PE), mortality, and adverse events KQ 3: VTE events (DVT and/or PE) KQ 4: Staff- or patient-reported ease of use or adherence | –
Timing | Outcomes reported at ≥4 weeks from randomization or study enrollment^*^ | Outcomes reported at <4 weeks
Setting | Hospitalized patients in North America, the European Union, Australia, New Zealand, or Japan^†^ | Outpatients or studies conducted in countries not listed as eligible
Design | KQ 1, KQ 2, and KQ 3: RCTs KQ 4: RCTs and quasi-experimental or cohort studies | –
Other | Publication year 1995 or later^‡^ English-language publication | –

* Rationale was that approximately 15% of DVTs occur post-hospitalization.

† Rationale was to include economically developed countries with sufficient similarities in healthcare system and culture to be applicable to U.S. medical care.

‡ Studies prior to 1995 were excluded because surgical procedures and post-operative care have changed substantially since then, and these changes affect the risk of VTE.

Abbreviations: DVT=deep vein thrombosis; FXa=factor Xa; IPCD=intermittent pneumatic compression device; KQ=key question; LMWH=low molecular weight heparin; PE=pulmonary embolism; RCTs=randomized controlled trials; THA=total hip arthroplasty; TKA=total knee arthroplasty; VTE=venous thromboembolism

## DATA ABSTRACTION

Data from included articles were abstracted into the final form by a trained investigator and confirmed by a second investigator. Data elements abstracted included patient descriptors; setting, features, and dose of the intervention (including timing and duration for IPCDs); characteristics of the comparator; outcomes; and risk of bias elements. All data abstractions were confirmed by a second investigator. Disagreements were resolved by consensus or by obtaining a third investigator's opinion. When data were incomplete or missing, we contacted authors to request the data.

## QUALITY ASSESSMENT

We assessed the quality (risk of bias) of each study and summarized the overall risk of bias for each study as low, moderate, or high. We used the key risk of bias criteria described in the Agency for Healthcare Research and Quality's Methods Guide for Effectiveness and Comparative Effectiveness Reviews,41 adapted to this specific topic (Appendix B). The key criteria for RCTs are: adequacy of randomization and allocation concealment; comparability of groups at baseline; blinding; completeness of follow-up and differential loss to follow-up; whether incomplete data were addressed appropriately; validity of outcome measures; and conflict of interest. Observational studies were evaluated using the following domains: basic study design, selection bias, performance bias, attrition bias, and detection bias.

## DATA SYNTHESIS

We grouped studies into those that enrolled participants undergoing joint replacement, other surgery, and medical patients.

When meta-analysis was feasible, we computed summary estimates of effect. We used R (R Foundation for Statistical Computing, Vienna, Austria) with the metafor package42 to calculate the summary estimates of treatment effect. Dichotomous outcomes were analyzed using summary risk ratios (RRs). We used a random-effects model and due to the relatively small number of studies we utilized the Knapp and Hartung method to adjust the standard errors of the estimated coefficients.43,44 We evaluated for statistical heterogeneity in treatment effects using Cochran's Q and I^2^ statistics. We planned subgroup analyses to explore potential sources of heterogeneity, specifying a priori: foot, calf, or thigh location of the IPCD; concurrent use of anticoagulation; and risk of bias elements. In some instances, planned subgroup analyses could not be performed because subgroups did not meet the pre-specified minimum of 3 studies per subgroup. When there were at least 3 studies at low or moderate risk of bias, we performed sensitivity analyses to compute summary estimates after excluding studies at high risk of bias. Publication bias was assessed using findings from a search of ClinicalTrials.gov. Funnel plots were not used because analyses did not meet the minimum threshold of at least 10 studies for meaningful analysis.41

Where quantitative synthesis was not feasible, we analyzed the data qualitatively. We gave more weight to evidence from higher-quality studies. We focused on identifying patterns in the efficacy and safety of the interventions and finding potential reasons for inconsistency in treatment effects.

## RATING THE BODY OF EVIDENCE

In addition to rating the quality of individual studies, we evaluated the overall strength of evidence for selected outcomes (mortality, VTE, symptomatic or asymptomatic DVT, and major bleeding) as high, moderate, low, or insufficient using the domains: risk of bias, directness, consistency of treatment effects, precision of treatment effects, and risk of publication bias.45 These domains were considered qualitatively, and a summary rating of high, moderate, low, or insufficient strength of evidence was assigned after discussion by 2 investigators. The 4-level rating scale consists of the following definitions:

- High—We are very confident that the true effect lies close to the estimate of the effect.
- Moderate—We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.
- Low—Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.
- Insufficient—Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

To evaluate the evidence for specific IPCDs or class of devices (eg, calf device), we considered head-to-head comparisons, indirect comparisons of IPCDs to a common comparator (eg, foot vs calf devices, each compared to anticoagulation), and observational data about ease of use or patient comfort. We calculated risk differences (RDs) for outcomes with strength of evidence ratings of low or higher. We used the pooled estimate of effect and baseline event rates from the literature (VTE, 4.3%^16^) or from the event rate in the anticoagulation arms of the included studies (DVT).

## PEER REVIEW

A draft of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is provided in Appendix C.