# INTRODUCTION

Venous thromboembolism (VTE), which encompasses deep vein thrombosis (DVT) and pulmonary embolism (PE), is a serious potential complication in hospitalized patients. In high-risk groups, such as post-operative surgical patients and acutely ill medical patients,1-5 VTE is a leading cause of morbidity and mortality.6-8 VTE prophylaxis is recommended for approximately 60% of high-risk surgical patients and for the 40% of hospitalized medical patients at risk for VTE.9,10

Clinical practice guidelines generally recommend either pharmacological or mechanical VTE prophylaxis. Pharmacological options include anticoagulation (eg, low molecular weight heparin [LMWH], new oral anticoagulants, or warfarin) and aspirin, but these may increase the risk of bleeding.11,12 Mechanical prophylaxis with intermittent pneumatic compression devices (IPCDs) is recommended, particularly in populations at high risk of bleeding,13-16 due to the decreased risk of major bleeding and surgical site bleeding associated with IPCDs.17-19 Although IPCDs can offer protection against VTE,20-22 compliance is often suboptimal,23,24 and efficacy may vary importantly across various devices.

## HIGH-RISK PATIENT POPULATIONS

In hospitalized medical patients, risk factors for VTE include trauma, malignancy, stroke, prior VTE, and congestive heart failure.25 In surgical populations, lower limb joint replacement surgery in particular is associated with an increased risk of VTE.25 Without prophylaxis, the incidence of 35-day symptomatic VTE events following orthopedic surgeries is high, with an estimated baseline rate of 4.3%.16 While the risk of symptomatic VTE is highest in the first 6 weeks following surgery, this risk can remain elevated for up to 2 to 3 months following surgery.26 Given this natural history, it is important to examine the effects of VTE prophylaxis beyond the period of hospitalization.

## INTERMITTENT PNEUMATIC COMPRESSION DEVICES

It is hypothesized that IPCDs prevent DVT formation through 2 mechanisms, namely, by decreasing venous stasis and activating fibrinolysis.27-29 These effects can be achieved by mechanical compression of the foot or calf alone, or by sequential compression of either the foot and calf, or the calf and thigh.

There are a wide variety of IPCDs currently available that differ in anatomical location of the sleeve garment, number and location of air bladders, patterns of compression cycles, and duration of inflation time and deflation time.30,31 In general, IPCDs can be categorized into either single-chamber or multi-chamber devices, constant pressure or sequential pressure devices, slow-gradual or rapid inflation devices, and portable or non-portable devices. Portable IPCDs offer the potential advantage of continued use during ambulation in the early post-operative period.32 By contrast, non-portable devices must be removed when the patient ambulates. Some devices also include an hour meter that may facilitate adherence monitoring. Although some clinical guidelines recommend certain device features such as portability,16 in general, guidelines do not make recommendations for or against specific IPCDs or device categories. Therefore, it remains unclear which of these approaches works best for specific patient populations. Consequently, clinicians and health systems routinely struggle with the selection of IPCDs.

## OBJECTIVES OF THE REPORT

This study was nominated by the Veterans Affairs (VA) National Surgery Office and Office of Nursing with the aim of evaluating IPCDs to inform best practice strategies, policy, and selection of devices for the VA Health System. The objective of this report is to evaluate the comparative effectiveness of IPCDs in post-operative surgical and high-risk medical patients of high interest to the Veterans Health Administration (VHA). There is a major gap in the existing literature on which specific populations will benefit from IPCD prophylaxis, and whether IPCDs vary importantly in VTE outcomes, adherence, and ease of use. This study addresses these gaps with a methodologically sophisticated systematic review.