# ABBREVIATIONS TABLE

ACCP: American College of Chest Physicians
CECT: Continuous enhanced circulation therapy
CI: Confidence interval
DVT: Deep vein thrombosis
ECRI: Emergency Care Research Institute
ESP: Evidence-based Synthesis Program
HSR&D: Health Services Research & Development
IPCD: Intermittent pneumatic compression device
ISTH: International Society on Thrombosis and Haemostasis
KQ: Key question
LMWH: Low molecular weight heparin
MeSH: Medical Subject Heading
n: Number
PE: Pulmonary embolism
PICOTS: Population, intervention, comparator, outcomes, timing, and setting
PTT: Partial thromboplastin time
QUERI: Quality Enhancement Research Initiative
RIAC: Rapid inflation asymmetrical compression
RCT: Randomized controlled trial
RD: Risk difference
RR: Risk ratio
SCD: Sequential compression device
THA: Total hip arthroplasty
TKA: Total knee arthroplasty
VA: Veterans Affairs
VHA: Veterans Health Administration
VISN: Veterans Integrated Service Networks
VTE: Venous thromboembolism
V/Q: Ventilation/perfusion