# TECHNICAL FEATURES OF NAMED DEVICES EVALUATED IN INCLUDED STUDIES

Manufacturer | Device Name | Sleeve Location | Single vs Multiple (Bladder Position) | Average Cycle Duration | Average Compression Duration | Pressure Pattern (Constant vs Sequential) and Amount | Inflation Rise Time (Rapid vs Slow) | Portable? | Hour Meter?
Aircast | VenaFlow^®^ | Calf^*^ | Multiple | 60 sec | 6 sec | Sequential; 52 mm Hg (distal), 45 mm Hg (proximal) | Rapid | No | Yes
Huntleigh | Flowtron^®^ | Calf^*^ | Single | 60 sec | 12 sec | Constant; 30-60 mm Hg | Slow | No^†^ | No
Jobst | Anthrombic Pump (System 2500)^‡^ | Calf^§^ | Multiple | 60 sec | 7-8 sec | Sequential; 30-50 mm Hg | Slow | No | No
NuTech | PlexiPulse^®^ | Foot, foot-calf║ | Multiple | Varies: 20-60 sec | 2.5 sec | Constant; 160 mm Hg | Rapid | No | Yes (1 study) No (2 studies)
Kendall | Kendall SCD™ | Calf, calf-thigh^#^ | Multiple | Varies; 20-60 sec | 11 sec | Sequential; 30-45 mm Hg | Slow | No^†^ | No
Medical Compression Systems | ActiveCare DVT^®^ or ActiveCare+S.F.T^®^ CECTs | Calf^*^ | Multiple | Varies; 30-60 sec | 10 sec | Sequential; Average maximum 50 mm Hg | Slow | Yes | Yes
Medical Compression Systems | WizAir DVT™ CECT | Calf | Multiple | 60 sec | 8 sec | Sequential; average maximum 50 mm Hg | Slow | Yes | Yes
Novamedix | A-V Impulse System™ | Foot | Single (sole of foot) | Varies: 20-50 sec | 3 sec | Constant; 60-200 mm Hg | Rapid | No | Yes

* Sleeves also available for foot and calf-thigh locations.

† Device available in both portable and non-portable options; answer given here is for the specific devices evaluated in the included studies.

‡ Specific information on this device was not provided in the published study included in our report, but rather by Huntleigh the company that most recently bought out Jobst.

§ Sleeve also available for calf-thigh location.

║ Sleeve also available for calf location.

# Sleeve also available for foot location.

Abbreviations: CECT(s)=continuous enhanced circulation therapy device(s); DVT=deep vein thrombosis; SCD=sequential compression device; S.F.T.=Synchronized Flow Technology