# STUDY CHARACTERISTICS

[underlined: Study Information] Author, year Number randomized Risk of bias KQ(s) | [underlined: Population] Country Procedure Sex (mean % men) Age (mean [range]) | [underlined: Intervention (IPCD)] Device Location Initiation Duration | [underlined: Comparator] Name Dosage or location Initiation Duration | [underlined: Adjunctive Therapy]^*^ ASA GCS Other
Blanchard, 1999^52^ 130 High KQ 1 | Switzerland TKA 23.8% 73 (49-88) | A-V Impulse System™ Foot 12 hours pre-op 8-12 days | LMWH (nadroparin) 2850-5700 IU daily 12 hours pre-op 10-12 days | NR No Acenocoumarol after 8-12 days over 6-8 weeks
Bockheim, 2009^60^ 150 High KQ 4 | United States Trauma 51% 62 (NR) | SCD Calf NR NR | Venous pump Foot NR NR | NR NR NR
Colwell, 2010^17^ 386 or 392 Moderate KQ 1 | United States THA 45% 63 (20-88) | ActiveCare+S.F.T.® Calf Intra-op 10 days post-op | LMWH (enoxaparin) 30 mg per 12 hours to discharge, then 40 mg daily 1 day post-op 10 days post-op | 81 mg/day allowed No NR
Edwards, 2008^58^ 277 High KQ 1 | United States TKA, THA 42.5% 68 (32-88) | ActiveCare DVT® Calf Intra-op To discharge | LMWH (enoxaparin) 30 mg per 12 hours 1 day post-op 8 days post-op | NR No Intervention: Enoxaparin 30 mg per 12 hours until 8 days post-op
Ginzburg, 2003^55^ 442 Moderate KQ 2 | United States Trauma 74.0% 41.5 (NR) | Flowtron® Calf Post-op within 24 hours 30 days, discharge, or death | LMWH (enoxaparin) 30 mg per 12 hours Post-op within 24 hours 30 days, discharge, or death | NR No NR
Greenfield, 1997^61^ 53 High KQ 2 | United States Trauma 60.4% 44 (NR) | IPCD Calf Post-admission Up to 4 weeks | Low dose unfractionated heparin 5000 U SC twice daily Post-admission Up to 4 weeks | NR NR Intervention: AV foot pump Comparator: LMWH
Lachiewicz, 2004^46^ 423 Moderate KQ 3 | United States TKA 35.5% 66.8 (23-94) | VenaFlow® Calf During surgery NR, probably discharge | Kendall SCD™ Calf During surgery NR, probably discharge | 325 mg pre-op; 650 mg twice daily, post-op Yes Continuous passive movement machine, 1 hour, 3 times daily
Murakami, 2003^23^ 33 Moderate KQ 4 | United States Trauma 60.6% 48.4 (NR) | WizAir DVT™ CECT Calf Immediately post-randomization NR | Kendall SCD Calf Immediately post-randomization NR | NR NR Addition of heparin at the discretion of the MD
Pagella, 2007^47^ 65 Moderate KQ 4 | United States THA or TKA 41.5% 57.6 (NR) | Kendall SCD Calf NR NR | Flowtron Calf NR NR | NR Allowed Warfarin, LMWH, unfractionated heparin, and IVC filters also allowed
Pambianco, 1995^59^ 360 Moderate KQ 2 | United States Stroke patients 41.5% 71.4 (NR) | Anthrombic pump (Jobst) Calf Post-admission Discharge or day 28 | Adjusted dose heparin; 5000-10,000 U SC every 8 hours Post-admission Discharge or day 28 | NR Yes NR
Pitto, 2004^18^ 216 Moderate KQ 1 | New Zealand THA 31% 57.7 (NR) | A-V Impulse System Foot Post-op, in recovery room NR | LMWH (nadroparin) NR Post-op, in recovery room Until discharge | NR Yes LMWH given to both groups at 12 hours pre-op
Proctor, 2001^62^ 1350 High KQ 4 | United States Surgical & medical NR 54.3 (NR) | NR Foot, calf, or calf-thigh Admission Discharge or 30 days | NR Foot, calf, or calf-thigh Admission Discharge or 30 days | NR Allowed Heparin allowed
Robertson, 2000^48^ 224 High KQ 4 | United States THA or TKA NR NR | Kendall SCD Calf-thigh NR NR | PlexiPulse® Foot NR NR | NR Yes with Intervention, NR with Comparator Enoxaparin and warfarin allowed per MD
Rokito, 1996^49^ 110 Moderate KQ 1 | United States Spinal surgery 39.5% 44.5 (22-77) | Kendall SCD Calf-thigh Intra-op (“at surgery”) 5-7 days post-op | Warfarin 10 mg Day before surgery 5-7 days post-op | NR Yes No
Silbersack, 2004^57^ 131 Moderate KQ 1 | Germany THA or TKA 35.7% 64 (29-90) | VenaFlow Calf Immediately post-op NR | LMWH (enoxaparin) 40 mg daily Evening prior to surgery 30 days | Allowed Yes (Comparator only) Intervention: Enoxaparin 40 mg daily until 30 days
Stannard, 2001^50^ 107 Moderate KQs 3 and 4 | United States Trauma NR NR | Kendall SCD Calf-thigh <72 hours from injury NR | PlexiPulse Calf-foot <72 hours from injury NR | No NR NR
Stone, 1996^56^ 50 Moderate KQ 1 | United Kingdom THA NR NR | Flowtron Calf Immediately post-op NR | LMWH (enoxaparin) 40 mg daily Evening prior to surgery Until discharge | No NR NR
Warwick, 2002^19^ 229 Moderate KQ 1 | United Kingdom TKA 40% 72 (NR) | A-V Impulse System Foot In recovery room Until discharge | LMWH (enoxaparin) 40 mg daily 12 hours pre-op Until discharge | Allowed Yes NR
Warwick, 1998^53^ 290 Moderate KQ 1 | United Kingdom THA 62.5% 68 (NR) | A-V Impulse System Foot In recovery room 7 days post-op | LMWH (enoxaparin) 40 mg daily 12 hours pre-op 7 days post-op | Allowed Yes NR
Windisch, 2011^54^ 80 Moderate KQ 1 | Germany TKA NR 68.9 | A-V Impulse System Foot Immediately post-op 8 days post-op | LMWH (enoxaparin) 40 mg daily 24 hours pre-op 8 days post-op | Yes NR Intervention: Enoxaparin 40 mg daily until 8 days post-op
Wood, 1997^51^ 136 High KQs 3 and 4 | United States Spinal surgery 59% 39.5 (NR) | PlexiPulse Foot Intra-op or at surgery Until discharge | Kendall SCD Calf-thigh Post-op Until discharge | NR Yes No

* Adjunctive therapies (ASA, GCS, or Other) apply to both Intervention and Comparator groups unless otherwise noted.

Abbreviations: ASA=acetylsalicylic acid (aspirin); AV=arteriovenous; CECT=Continuous Enhanced Circulation Therapy; GCS=graduated compression stockings; IPCD=intermittent pneumatic compression device; IVC=inferior vena cava; KQ(s)=key question(s); LMWH=low molecular weight heparin; NR=not reported; PCD=pneumatic compression device; SC=subcutaneously; SCD=sequential compression device; S.F.T.=Synchronized Flow Technology; THA=total hip arthroplasty; TKA=total knee arthroplasty

## References to Appendix D

1 Cohen AT, Agnelli G, Anderson FA, et al. Venous thromboembolism (VTE) in Europe. The number of VTE events and associated morbidity and mortality. Thromb Haemost. Oct. 2007;98(4):756-764. [pmid: 17938798].
2 Beckman MG, Hooper WC, Critchley SE, Ortel TL. Venous thromboembolism: a public health concern. Am J Prev Med. Apr. 2010;38(4 Suppl):S495-501. [pmid: 20331949].
3 Kim YH, Oh SH, Kim JS. Incidence and natural history of deep-vein thrombosis after total hip arthroplasty. A prospective and randomised clinical study. J Bone Joint Surg Br. Jul. 2003;85(5):661-665. [pmid: 12892186].
4 O'Reilly RF, Burgess IA, Zicat B. The prevalence of venous thromboembolism after hip and knee replacement surgery. Med J Aust. Feb. 21. 2005;182(4):154-159. [pmid: 15720169].
5 Oda T, Fuji T, Kato Y, Fujita S, Kanemitsu N. Deep venous thrombosis after posterior spinal surgery. Spine (Phila Pa 1976). Nov. 15. 2000;25(22):2962-2967. [pmid: 11074685].
6 Geerts WH, Pineo GF, Heit JA, et al. Prevention of venous thromboembolism: the Seventh ACCP Conference on Antithrombotic and Thrombolytic Therapy. Chest. Sep. 2004;126(3 Suppl):338s-400s. [pmid: 15383478].
7 Kahn SR, Hirsch A, Shrier I. Effect of postthrombotic syndrome on health-related quality of life after deep venous thrombosis. Arch Intern Med. May. 27. 2002;162(10):1144-1148. [pmid: 12020185].
8 Pengo V, Lensing AW, Prins MH, et al. Incidence of chronic thromboembolic pulmonary hypertension after pulmonary embolism. N Engl J Med. May. 27. 2004;350(22):2257-2264. [pmid: 15163775].
9 Anderson FA Jr., Zayaruzny M, Heit JA, Fidan D, Cohen AT. Estimated annual numbers of US acute-care hospital patients at risk for venous thromboembolism. Am J Hematol. Sep. 2007;82(9):777-782. [pmid: 17626254].
10 Cohen AT, Tapson VF, Bergmann JF, et al. Venous thromboembolism risk and prophylaxis in the acute hospital care setting (ENDORSE study): a multinational cross-sectional study. Lancet. Feb. 2. 2008;371(9610):387-394. [pmid: 18242412].
11 Qaseem A, Chou R, Humphrey LL, Starkey M, Shekelle P. Venous thromboembolism prophylaxis in hospitalized patients: a clinical practice guideline from the American College of Physicians. Ann Intern Med. Nov. 1. 2011;155(9):625-632. [pmid: 22041951].
12 Adam SS, McDuffie JR, Lachiewicz PF, Ortel TL, Williams JW Jr. Comparative effectiveness of new oral anticoagulants and standard thromboprophylaxis in patients having total hip or knee replacement: a systematic review. Ann Intern Med. Aug. 20. 2013;159(4):275-284. [pmid: 24026260].
13 Kahn SR, Lim W, Dunn AS, et al. Prevention of VTE in nonsurgical patients: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):el95S-226S.
14 Mont MA, Jacobs JJ. AAOS clinical practice guideline: preventing venous thromboembolic disease in patients undergoing elective hip and knee arthroplasty. J Am Acad Orthop Surg. Dec. 2011;19(12):777-778. [pmid: 22134210].
15 Gould MK, Garcia DA, Wren SM, et al. Prevention of VTE in nonorthopedic surgical patients: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):e227S-277S. [pmid: 22315263].
16 Falck-Ytter Y, Francis CW, Johanson NA, et al. Prevention of VTE in orthopedic surgery patients: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):e278S-325S. [pmid: 22315265].
17 Colwell CW Jr., Froimson MI, Mont MA, et al. Thrombosis prevention after total hip arthroplasty: a prospective, randomized trial comparing a mobile compression device with low-molecular-weight heparin. J Bone Joint Surg Am. Mar. 2010;92(3):527-535. [pmid: 20194309].
18 Pitto RP, Hamer H, Heiss-Dunlop W, Kuehle J. Mechanical prophylaxis of deep-vein thrombosis after total hip replacement a randomised clinical trial. J Bone Joint Surg Br. Jul. 2004;86(5):639-642. [pmid: 15274256].
19 Warwick D, Harrison J, Whitehouse S, Mitchelmore A, Thornton M. A randomised comparison of a foot pump and low-molecular-weight heparin in the prevention of deep-vein thrombosis after total knee replacement. J Bone Joint Surg Br. Apr. 2002;84(3):344-350. [pmid: 12002490].
20 Ho KM, Tan JA. Stratified meta-analysis of intermittent pneumatic compression of the lower limbs to prevent venous thromboembolism in hospitalized patients. Circulation. Aug. 27. 2013;128(9):1003-1020. [pmid: 23852609].
21 Kakkos SK, Warwick D, Nicolaides AN, Stansby GP, Tsolakis IA. Combined (mechanical and pharmacological) modalities for the prevention of venous thromboembolism in joint replacement surgery. J Bone Joint Surg Br. Jun. 2012;94(6):729-734. [pmid: 22628585].
22 Glotzbecker MP, Bono CM, Wood KB, Harris MB. Thromboembolic disease in spinal surgery: a systematic review. Spine (Phila Pa 1976). Feb. 1. 2009;34(3):291-303. [pmid: 19179925].
23 Murakami M, McDill TL, Cindrick-Pounds L, et al. Deep venous thrombosis prophylaxis in trauma: improved compliance with a novel miniaturized pneumatic compression device. J Vasc Surg. Nov. 2003;38(5):923-927. [pmid: 14603195].
24 Cornwell EE 3rd, Chang D, Velmahos G, et al. Compliance with sequential compression device prophylaxis in at-risk trauma patients: a prospective analysis. Am Surg. May. 2002;68(5):470-473. [pmid: 12017149].
25 Anderson FA Jr., Spencer FA. Risk factors for venous thromboembolism. Circulation. Jun. 17. 2003;107(23 Suppl 1):I9-16. [pmid: 12814980].
26 Kearon C. Natural history of venous thromboembolism. Circulation. Jun. 17. 2003;107(23 Suppl 1):I22-30. [pmid: 12814982].
27 Malone MD, Cisek PL, Comerota AJ Jr., Holland B, Eid IG, Comerota AJ. High-pressure, rapid-inflation pneumatic compression improves venous hemodynamics in healthy volunteers and patients who are post-thrombotic. J Vasc Surg. Apr. 1999;29(4):593-599. [pmid: 10194485].
28 Comerota AJ, Chouhan V, Harada RN, et al. The fibrinolytic effects of intermittent pneumatic compression: mechanism of enhanced fibrinolysis. Ann Surg. Sep. 1997;226(3):306-313. discussion 313-304. [pmid: 9339937].
29 Kohro S, Yamakage M, Sato K, Sato JI, Namiki A. Intermittent pneumatic foot compression can activate blood fibrinolysis without changes in blood coagulability and platelet activation. Acta Anaesthesiol Scand. May. 2005;49(5):660-664. [pmid: 15836680].
30 Zhao JM, He ML, Xiao ZM, Li TS, Wu H, Jiang H. Different types of intermittent pneumatic compression devices for preventing venous thromboembolism in patients after total hip replacement. Cochrane Database Syst Rev. 2012;11. CD009543.
31 Westrich GH, Specht LM, Sharrock NE, et al. Pneumatic compression hemodynamics in total hip arthroplasty. Clin Orthop Relat Res. Mar. 2000;(372):180-191. [pmid: 10738427].
32 Colwell CW Jr., Froimson MI, Anseth SD, et al. A mobile compression device for thrombosis prevention in hip and knee arthroplasty. J Bone Joint Surg Am. Feb. 5. 2014;96(3):177-183. [pmid: 24500578].
33 Lefebvre C, Manheimer E, Glanville J. Chapter 6: Searching for studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. (updated March 2011). The Cochrane Collaboration. 2011. www.cochrane-handbook.org. July 22, 2014.
34 Agarwal R, Hecht TE, Lazo MC, Umscheid CA. Venous thromboembolism prophylaxis for patients undergoing bariatric surgery: a systematic review. Surg Obes Relat Dis. Mar. 4. 2010;6(2):213-220. [pmid: 20176509].
35 Kakkos SK, Caprini JA, Geroulakos G, Nicolaides AN, Stansby GP, Reddy DJ. Combined intermittent pneumatic leg compression and pharmacological prophylaxis for prevention of venous thromboembolism in high-risk patients. Cochrane Database Syst Rev. 2008;(4). CD005258.
36 Lederle FA, Zylla D, MacDonald R, Wilt TJ. Venous thromboembolism prophylaxis in hospitalized medical patients and those with stroke: a background review for an American College of Physicians Clinical Practice Guideline. Ann Intern Med. Nov. 1. 2011;155(9):602-615. [pmid: 22041949].
37 Morris RJ, Woodcock JP. Intermittent pneumatic compression or graduated compression stockings for deep vein thrombosis prophylaxis? A systematic review of direct clinical comparisons. Ann Surg. Mar. 2010;251(3):393-396. [pmid: 20083996].
38 Naccarato M, Chiodo Grandi F, Dennis M, Sandercock PA. Physical methods for preventing deep vein thrombosis in stroke. Cochrane Database Syst Rev. 2010;(8). CD001922.
39 Pour AE, Keshavarzi NR, Purtill JJ, Sharkey PF, Parvizi J. Is venous foot pump effective in prevention of thromboembolic disease after joint arthroplasty: a meta-analysis. J Arthroplasty. Mar. 2013;28(3):410-417. [pmid: 23102505].
40 Rahn DD, Mamik MM, Sanses TV, et al. Venous thromboembolism prophylaxis in gynecologic surgery: a systematic review. Obstet Gynecol. Nov. 2011;118(5):1111-1125. [pmid: 22015880].
41 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. November 6, 2014.
42 Viechtbauer W. Conducting meta-analyses in R with the metafor package. Journal of Statistical Software. 2010;36(3):1-48.
43 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-188. [pmid: 3802833].
44 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. Sep. 15. 2003;22(17):2693-2710. [pmid: 12939780].
45 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol. Apr. 2011;64(4):383-394. [pmid: 21195583].
46 Lachiewicz PF, Kelley SS, Haden LR. Two mechanical devices for prophylaxis of thromboembolism after total knee arthroplasty. A prospective, randomised study. J Bone Joint Surg Br. Nov. 2004;86(8):1137-1141. [pmid: 15568526].
47 Pagella P, Cipolle M, Sacco E, Matula P, Karoly E, Bokovoy J. A randomized trial to evaluate compliance in terms of patient comfort and satisfaction of two pneumatic compression devices. Orthop Nurs. May-Jun. 2007;26(3):169-174. [pmid: 17538472].
48 Robertson KA, Bertot AJ, Wolfe MW, Barrack RL. Patient compliance and satisfaction with mechanical devices for preventing deep venous thrombosis after joint replacement. J South Orthop Assoc. Fall. 2000;9(3):182-186. [pmid: 12135300].
49 Rokito SE, Schwartz MC, Neuwirth MG. Deep vein thrombosis after major reconstructive spinal surgery. Spine (Phila Pa 1976). Apr. 1. 1996;21(7):853-858. discussion 859. [pmid: 8779018].
50 Stannard JP, Riley RS, McClenney MD, Lopez-Ben RR, Volgas DA, Alonso JE. Mechanical prophylaxis against deep-vein thrombosis after pelvic and acetabular fractures. J Bone Joint Surg Am. Jul. 2001;83-a(7):1047-1051. [pmid: 11451974].
51 Wood KB, Kos PB, Abnet JK, Ista C. Prevention of deep-vein thrombosis after major spinal surgery: a comparison study of external devices. J Spinal Disord. Jun. 1997;10(3):209-214. [pmid: 9213276].
52 Blanchard J, Meuwly JY, Leyvraz PF, et al. Prevention of deep-vein thrombosis after total knee replacement. Randomised comparison between a low-molecular-weight heparin (nadroparin) and mechanical prophylaxis with a foot-pump system. J Bone Joint Surg Br. Jul. 1999;81(4):654-659. [pmid: 10463739].
53 Warwick D, Harrison J, Glew D, Mitchelmore A, Peters TJ, Donovan J. Comparison of the use of a foot pump with the use of low-molecular-weight heparin for the prevention of deep-vein thrombosis after total hip replacement. A prospective, randomized trial. J Bone Joint Surg Am. Aug. 1998;80(8):1158-1166. [pmid: 9730125].
54 Windisch C, Kolb W, Kolb K, Grutzner P, Venbrocks R, Anders J. Pneumatic compression with foot pumps facilitates early postoperative mobilisation in total knee arthroplasty. Int Orthop. Jul. 2011;35(7):995-1000. [pmid: 20652250].
55 Ginzburg E, Cohn SM, Lopez J, Jackowski J, Brown M, Hameed SM. Randomized clinical trial of intermittent pneumatic compression and low molecular weight heparin in trauma. Br J Surg. Nov. 2003;90(11):1338-1344. [pmid: 14598411].
56 Stone MH, Limb D, Campbell P, Stead D, Culleton G. A comparison of intermittent calf compression and enoxaparin for thromboprophylaxis in total hip replacement. A pilot study. Int Orthop. 1996;20(6):367-369. [pmid: 9049766].
57 Silbersack Y, Taute BM, Hein W, Podhaisky H. Prevention of deep-vein thrombosis after total hip and knee replacement. Low-molecular-weight heparin in combination with intermittent pneumatic compression. J Bone Joint Surg Br. Aug. 2004;86(6):809-812. [pmid: 15330019].
58 Edwards JZ, Pulido PA, Ezzet KA, Copp SN, Walker RH, Colwell CW Jr. Portable compression device and low-molecular-weight heparin compared with low-molecular-weight heparin for thromboprophylaxis after total joint arthroplasty. J Arthroplasty. Dec. 2008;23(8):1122-1127. [pmid: 18534421].
59 Pambianco G, Orchard T, Landau P. Deep vein thrombosis: prevention in stroke patients during rehabilitation. Arch Phys Med Rehabil. Apr. 1995;76(4):324-330. [pmid: 7717832].
60 Bockheim HM, McAllen KJ, Baker R, Barletta JF. Mechanical prophylaxis to prevent venous thromboembolism in surgical patients: a prospective trial evaluating compliance. J Crit Care. Jun. 2009;24(2):192-196. [pmid: 19327952].
61 Greenfield LJ, Proctor MC, Rodriguez JL, Luchette FA, Cipolle MD, Cho J. Posttrauma thromboembolism prophylaxis. J Trauma. Jan. 1997;42(1):100-103. [pmid: 9003265].
62 Proctor MC, Greenfield LJ, Wakefield TW, Zajkowski PJ. A clinical comparison of pneumatic compression devices: the basis for selection. J Vasc Surg. Sep. 2001;34(3):459-463. discussion 463-454. [pmid: 11533598].
63 Schulman S, Angeras U, Bergqvist D, Eriksson B, Lassen MR, Fisher W. Definition of major bleeding in clinical investigations of antihemostatic medicinal products in surgical patients. J Thromb Haemost. Jan. 2010;8(1):202-204. [pmid: 19878532].
64 Kurtz S, Ong K, Lau E, Mowat F, Halpern M. Projections of primary and revision hip and knee arthroplasty in the United States from 2005 to 2030. J Bone Joint Surg Am. Apr. 2007;89(4):780-785. [pmid: 17403800].
65 Amin A, Stemkowski S, Lin J, Yang G. Thromboprophylaxis rates in US medical centers: success or failure?. J Thromb Haemost. Aug. 2007;5(8):1610-1616. [pmid: 17663733].
66 Tapson VF, Decousus H, Pini M, et al. Venous thromboembolism prophylaxis in acutely ill hospitalized medical patients: findings from the International Medical Prevention Registry on Venous Thromboembolism. Chest. Sep. 2007;132(3):936-945. [pmid: 17573514].
67 Schleyer AM, Schreuder AB, Jarman KM, Logerfo JP, Goss JR. Adherence to guideline-directed venous thromboembolism prophylaxis among medical and surgical inpatients at 33 academic medical centers in the United States. Am J Med Qual. May-Jun. 2011;26(3):174-180. [pmid: 21490270].
68 Herbers J, Zarter S. Prevention of venous thromboembolism in Department of Veterans Affairs hospitals. J Hosp Med. 2010;5(1):E21-E25. [pmid: 20063282].
69 Agha Z, Lofgren RP, VanRuiswyk JV, Layde PM. Are patients at Veterans Affairs medical centers sicker? A comparative analysis of health status and medical resource use. Arch Intern Med. Nov. 27. 2000;160(21):3252-3257. [pmid: 11088086].
70 Anonymous. Intermittent pneumatic compression devices. Health Devices. Jun. 2007;36(6):177-204. [pmid: 17696075].
71 Gelfer Y, Tavor H, Oron A, Peer A, Halperin N, Robinson D. Deep vein thrombosis prevention in joint arthroplasties: continuous enhanced circulation therapy vs low molecular weight heparin. J Arthroplasty. Feb. 2006;21(2):206-214. [pmid: 16520208].
72 Chin PL, Amin MS, Yang KY, Yeo SJ, Lo NN. Thromboembolic prophylaxis for total knee arthroplasty in Asian patients: a randomised controlled trial. J Orthop Surg (Hong Kong). Apr. 2009;17(1):1-5. [pmid: 19398783].
73 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.