# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Reviewer | Comment | Response
Question 1. Are the objectives, scope, and methods for this review clearly described?
1 | Yes | Acknowledged
2 | Yes | Acknowledged
3 | Yes | Acknowledged
4 | Yes | Acknowledged
6 | Yes | Acknowledged
Question 2. Is there any indication of bias in our synthesis of the evidence?
1 | No | Acknowledged
2 | No | Acknowledged
3 | No | Acknowledged
4 | No | Acknowledged
6 | No | Acknowledged
Question 3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No | Acknowledged
2 | No | Acknowledged
3 | No | Acknowledged
4 | No | Acknowledged
6 | Yes - Colwell report from 2014 JBJS of large cohort trial with IPCD | This article was identified in our search, but did not meet inclusion criteria at the comparator level. This Colwell study is a non-randomized registry trial that compares VTE events of an IPCD with published symptomatic rates for anticoagulants. This study, however, does not directly compare IPCDs with pharmacological prophylaxis, which is required for inclusion. Furthermore, this study did not report on outcomes of interest (such as ease of use or adherence) required for inclusion of nonrandomized trials in our review.
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | The purpose of the study that I had in mind when I asked for your assistance in evaluating pneumatic compression devices used to prevent DVT and PE in post-op surgical patients was for you to evaluate and critically compare the various devices used to provide compression. Since there were several different devices available using different modes of compression, my hope was that if one method was superior to the others we could identify it and direct the VA to use it preferentially. Your study was most helpful in that it shows, within the limits of the evaluation, that all of the devices provide similar prophylaxis for DVT and similar levels of comfort for the patient during their use. This was most helpful as it means that we should primarily select a device or pneumatic compression system on value which equals quality divided by cost. | Thank you. While the existing data do not allow any strong conclusions about differential effectiveness or ease of use, we noted other factors to consider: 1) Clinical guidelines from ACCP and AAOS, and 2) safety features, ease-of-use features, and most frequently studied devices. We have added a new table providing more details about the characteristics of the devices examined in the included studies (Appendix E).
2 | Word missing from line 14. “The committee is interested _____ developing policy....” | Thank you. This error has been corrected.
3 | [No comments submitted] | –
4 | Overall well done review and the reports in concise and transparent with appropriate methodology. | Thank you.
4 | Search date (consider an update) | An updated search is not part of the standard processes for the Evidence Synthesis Program.
4 | English language restriction is problematic. At a minimum there should be a rationale provided for doing so. | We restricted eligible studies to those published in English because we did not have the resources to translate non-English publications. Although this restriction introduces the chance of publication bias, we were reassured that the risk was low after reviewing a recent study without this restriction (Ho 2013) and finding that it had not identified any eligible non-English language studies.
4 | Agreement among reviewers is not reported or described (I apologize if I missed it). | Inter-rater agreement is not reported. However, in the methods section we specify, “All data abstractions were confirmed by a second investigator. Disagreements were resolved by consensus or by obtaining a third investigator's opinion.”
4 | Figure 1 (and other figures) that reference to the questions (KQ1, KQ2, etc) are hard to read. I suggest you add the question in a shortened format to remind readers. For example, you can say “KQ1-surgical patients”, etc. | Acknowledged. We modified the labels to reference the KQs in Figure 1, and we have clarified that the other figures reference surgical patients.
4 | Major bleeding in KQ1 is clearly not precise: RD=25 fewer (34 fewer to 19 more) and such direct evidence is clearly not moderate, but rather of low quality. Nonetheless, indirect evidence (from people treated with anticoagulation in other settings and conditions) tells us that bleeding risk increases with anticoagulation. So, in this case, the indirect evidence is probably better to use for the outcome of bleeding (you can list both in the evidence profile as two subsequent lines). | The denominator for this calculation was missing from the draft table and has been corrected to show a risk difference of 25 fewer per 1000 patients (34 fewer to 19 more). However, this RD was based on few events and we agree that this is an imprecise result. We have re-rated the SOE as “Low”. Although it is well established that long-term anticoagulation does increase the risk of bleeding, the SOE in Table 3 is based only on studies included in the current review.
6 | The report concludes that IPCD prophylaxis is equivalent to anticoagulation in prevention of VTE and that the risk of bleeding from using chemoprophylaxis is higher. Because ACCP guidelines recommend that IPCD devices be portable, battery powered and record compliance and because the ACCP guidelines have always been the gold standard for VTE prophylaxis recommendations in orthopaedics, a comparison of various IPCD devices can be done by just comparing characteristics of each of the devices as to whether they all conform to these recommendations (only one device is portable, battery-powered and records compliance). Also, this device has documented efficacy in prevention of symptomatic VTE in a very large (>3000 total hip and knee patients) multicenter study that is similar (non-inferior) to that of LMWH. Also, several studies have been published indicating a higher rate of readmission in patients treated with chemoprophylaxis compared to IPCD, this fact should be presented in the study. | Our conclusions states, “Although IPCDs differ in practical features and in effects on physiology, current evidence does not show a clear difference in effects on clinically important outcomes.” In the discussion, we cite the ACCP guidelines and note that “for orthopedic procedures, portable battery powered IPCDs and devices capable of recording wear time are recommended as an option for patients at low risk of bleeding, but pharmacological prophylaxis with or without IPCD is preferred.” We give characteristics of devices evaluated in the studies included in this review (Table 2 and Appendix E)) but note that this is not a comprehensive listing of all the devices on the market. We believe the multicenter study cited by the reviewer is Colwell et al, Journal of Bone and Joint Surgery, 2014;96: 177-83. This study was identified by our search and excluded because it is a non-randomized trial reporting VTE outcomes. It also does not report any outcomes required for inclusion of non-randomized studies. Readmission was not an outcome identified by our content experts or stakeholders. Further, it is a potentially problematic outcome because many factors contribute to rehospitalization.
| Extra comments
1 | Extra comments from an email from Reviewer 1 on 05/18/15 (he turned in comments via the form on 05/27/15, so the comments below precede those): “I have read and re-read the results of your research into the effectiveness of the various types of pneumatic compression devices for DVT/PE prophylaxis in high risk surgical and medical patients. It is a truly excellent document - clearly written with easily comprehendable study objectives and outcomes. I was amazed to see how few studies out of the 1500+ total actually provided meaningful information. You have out done yourselves in providing me (and other clinicians, I suspect) with very useful information. It will help our team understand that most of the pneumatic compression devices perform well and with the exceptions you identify, we can recommend that the VA use competitive price for the basis for acquisition of these devices. My sincere thanks for all you effort and dedication. I will send any thoughts for improvement in the publication as I find them - if I can note any.” | Acknowledged. Thank you.