# QUALITY (RISK OF BIAS) ASSESSMENT OF RCTS—CRITERIA USED AND DETAILED RATINGS

General Instructions: Rate each risk of bias item listed below as Low risk/High risk/Unclear risk (see Cochrane guidance to inform judgements). Add comments to justify ratings. After considering each of the quality items, give the study an overall rating of “Low risk,” “Moderate risk,” or “High risk” (see below).

## Rating of individual items

1. Selection bias:
  a. [underlined: *Randomization adequate] (Adequate methods include: random number table, computer-generated randomization, minimization w/o a random element) Low risk/High risk/Unclear risk
  b. [underlined: *Allocation concealment] (Adequate methods include: pharmacy-controlled randomization, numbered sealed envelopes, central allocation) Low risk/High risk/Unclear risk
  c. [underlined: Baseline characteristics] (Consider whether there were systematic differences observed in baseline characteristics and prognostic factors between groups, and if important differences were observed, if the analyses controlled for these differences) Low risk/High risk/Unclear risk
2. Performance bias:
  a. [underlined: *Concurrent interventions or unintended exposures:] (Consider concurrent intervention or an unintended exposure [eg, crossovers; contamination – some control group gets the intervention] that might bias results) Low risk/High risk/Unclear risk
  b. [underlined: Protocol variation:] (Consider whether variation from the protocol compromised the conclusions of the study) Low risk/High risk/Unclear risk
3. Detection bias:
  a. [underlined: * Subjects Blinded?:] (Consider measures used to blind subjects to treatment assignment and any data presented on effectiveness of these measures) Low risk/High risk/Unclear risk
  b. [underlined: *Outcome assessors blinded (hard outcomes):] (Outcome assessors blind to treatment assignment for “hard outcomes” such as mortality) Low risk/High risk/Unclear risk
  c. [underlined: *Outcome assessors blinded (soft outcomes):] (Outcome assessors blind to treatment assignment for “soft outcomes” such as symptoms) Low risk/High risk/Unclear risk
  d. [underlined: Measurement bias:] (Reliability and validity of measures used-VTE) Low risk/High risk/Unclear risk
  e. [underlined: Measurement bias:] (Reliability and validity of measures used- Ease of use/Acceptability Low risk/High risk/Unclear risk
4. Attrition bias:
  a. [underlined: *Incomplete outcome data:] (Consider whether incomplete outcome data were adequately addressed, including: systematic differences in attrition between groups [differential attrition]; overall loss to follow-up [overall attrition]; and whether an “intention-to-treat” [ITT; all eligible patients that were randomized are included in analysis] analysis was performed) (Note – mixed models and survival analyses are in general ITT) Low risk/High risk/Unclear risk
5. Reporting bias:
  a. [underlined: *Selective outcomes reporting:] (Consider whether there is any suggestion of selective outcome reporting (eg, systematic differences between planned and reported findings)? Low risk/High risk/Unclear risk

*Items contained in Cochrane Risk of Bias Tool

## Overall study rating

Please assign each study an overall quality rating of “Low risk,” “High risk,” or “Unclear risk” based on the following definitions:

- A “Low risk” study has the least bias, and results are considered valid. A low risk study uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results. [Items 1a and 1c; 2a; 3b and 3c; and 4a are all rated low risk]
- A “Moderate risk” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems (unclear risk). As the moderate risk category is broad, studies with this rating vary in their strengths and weaknesses. [Most, but not all of the following items are rated low risk: Items 1a and 1c; 2a; 3b and 3c; and 4a]
- A “High risk” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a high risk study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions. [At least one-half of the individual quality items are rated high risk or unclear risk]

## Conflict of interest: (Record but not used as part of Risk of Bias Assessment)

a. [underlined: Was there the absence of potential important conflict of interest?:] The focus here is financial conflict of interest. If no financial conflict of interest (eg, if funded by government or foundation and authors do not have financial relationships with drug/device manufacturer), then answer “Yes.” Yes/No/Unclear

Appendix Table B1 Detailed Risk-of-Bias Ratings for Included RCTs^*^

Study | Individual Quality Assessment Criteria Ratings | | | | | | | | | | | | Overall Rating | COI Absent?
Study | 1a | 1b | 1c | 2a | 2b | 3a | 3b | 3c | 3d | 3e | 4 | 5 | Overall Rating | COI Absent?
Blanchard,1999^52^ | UR | LR | UR | LR | LR | LR | UR | UR | LR | UR | LR | LR | High | Yes
Colwell, 2010^17^ | LR | HR | LR | UR | LR | HR | LR | UR | LR | UR | LR | LR | Moderate | No
Edwards, 2008^58^ | UR | UR | LR | UR | HR | HR | UR | UR | LR | UR | UR | LR | High | No
Ginzburg, 2003^55^ | LR | UR | LR | LR | HR | LR | LR | UR | LR | UR | HR | LR | Moderate | Unclear
Greenfield, 1997^61^ | UR | UR | UR | LR | LR | LR | UR | UR | LR | UR | UR | UR | High | Unclear
Lachiewicz, 2004^46^ | UR | LR | LR | LR | LR | LR | LR | UR | LR | UR | LR | LR | Moderate | Yes
Murakami, 2003^23^ | LR | HR | LR | LR | LR | HR | UR | UR | LR | LR | LR | LR | Moderate | Yes
Pagella, 2007^47^ | LR | LR | LR | LR | LR | HR | UR | HR | UR | UR | LR | LR | Moderate | Unclear
Pambianco, 1995^59^ | LR | LR | LR | LR | LR | LR | UR | UR | LR | UR | HR | LR | Moderate | Yes
Pitto, 2004^18^ | LR | UR | LR | LR | UR | LR | LR | HR | LR | UR | HR | LR | Moderate | No
Rokito, 1996^49^ | UR | UR | LR | UR | LR | HR | LR | UR | UR | UR | LR | LR | Moderate | No
Silbersack, 2004^57^ | UR | UR | LR | UR | HR | LR | LR | UR | LR | UR | LR | LR | Moderate | No
Stannard, 2001^50^ | LR | UR | LR | UR | UR | UR | LR | UR | LR | UR | HR | LR | Moderate | No
Stone, 1996^56^ | UR | UR | LR | LR | UR | LR | UR | UR | LR | UR | UR | LR | Moderate | Unclear
Warwick,2002^19^ | LR | UR | LR | UR | UR | LR | LR | HR | LR | UR | UR | LR | Moderate | No
Warwick, 1998^53^ | LR | UR | LR | LR | HR | HR | LR | HR | LR | LR | LR | LR | Moderate | No
Windisch,2011^54^ | UR | UR | UR | LR | LR | HR | LR | UR | LR | UR | LR | LR | Moderate | Unclear
Wood, 1997^51^ | UR | UR | HR | UR | UR | HR | LR | HR | LR | UR | UR | LR | High | Unclear

* The quality rating criteria described above were not used for the 3 included observational studies.48,60,62 They were evaluated using the 5 domains of basic design, selection bias, performance bias, attrition bias, and detection bias, and only the overall score is reported in the body of the report.

Abbreviations: COI=conflict of interest; HR=high risk; LR=low risk; RCTs=randomized controlled trials; UR=unclear risk

## References to Appendix B

1 Blanchard J, Meuwly JY, Leyvraz PF, et al. Prevention of deep-vein thrombosis after total knee replacement. Randomised comparison between a low-molecular-weight heparin (nadroparin) and mechanical prophylaxis with a foot-pump system. J Bone Joint Surg Br. 1999;81(4):654-659. [pmid: 10463739].
2 Colwell CW Jr., Froimson MI, Mont MA, et al. Thrombosis prevention after total hip arthroplasty: a prospective, randomized trial comparing a mobile compression device with low-molecular-weight heparin. J Bone Joint Surg Am. 2010;92(3):527-535. [pmid: 20194309].
3 Edwards JZ, Pulido PA, Ezzet KA, Copp SN, Walker RH, Colwell CW Jr. Portable compression device and low-molecular-weight heparin compared with low-molecular-weight heparin for thromboprophylaxis after total joint arthroplasty. J Arthroplasty. 2008;23(8):1122-1127. [pmid: 18534421].
4 Ginzburg E, Cohn SM, Lopez J, Jackowski J, Brown M, Hameed SM. Randomized clinical trial of intermittent pneumatic compression and low molecular weight heparin in trauma. Br J Surg. 2003;90(11):1338-1344. [pmid: 14598411].
5 Greenfield LJ, Proctor MC, Rodriguez JL, Luchette FA, Cipolle MD, Cho J. Posttrauma thromboembolism prophylaxis. J Trauma. 1997;42(1):100-103. [pmid: 9003265].
6 Lachiewicz PF, Kelley SS, Haden LR. Two mechanical devices for prophylaxis of thromboembolism after total knee arthroplasty. A prospective, randomised study. J Bone Joint Surg Br. 2004;86(8):1137-1141. [pmid: 15568526].
7 Murakami M, McDill TL, Cindrick-Pounds L, et al. Deep venous thrombosis prophylaxis in trauma: improved compliance with a novel miniaturized pneumatic compression device. J Vasc Surg. 2003;38(5):923-927. [pmid: 14603195].
8 Pagella P, Cipolle M, Sacco E, Matula P, Karoly E, Bokovoy J. A randomized trial to evaluate compliance in terms of patient comfort and satisfaction of two pneumatic compression devices. Orthop Nurs. 2007;26(3):169-174. [pmid: 17538472].
9 Pambianco G, Orchard T, Landau P. Deep vein thrombosis: prevention in stroke patients during rehabilitation. Arch Phys Med Rehabil. 1995;76(4):324-330. [pmid: 7717832].
10 Pitto RP, Hamer H, Heiss-Dunlop W, Kuehle J. Mechanical prophylaxis of deep-vein thrombosis after total hip replacement a randomised clinical trial. J Bone Joint Surg Br. 2004;86(5):639-642. [pmid: 15274256].
11 Rokito SE, Schwartz MC, Neuwirth MG. Deep vein thrombosis after major reconstructive spinal surgery. Spine (Phila Pa 1976). 1996;21(7):853-858. discussion 859. [pmid: 8779018].
12 Silbersack Y, Taute BM, Hein W, Podhaisky H. Prevention of deep-vein thrombosis after total hip and knee replacement. Low-molecular-weight heparin in combination with intermittent pneumatic compression. J Bone Joint Surg Br. 2004;86(6):809-812. [pmid: 15330019].
13 Stannard JP, Riley RS, McClenney MD, Lopez-Ben RR, Volgas DA, Alonso JE. Mechanical prophylaxis against deep-vein thrombosis after pelvic and acetabular fractures. J Bone Joint Surg Am. 2001;83-a(7):1047-1051. [pmid: 11451974].
14 Stone MH, Limb D, Campbell P, Stead D, Culleton G. A comparison of intermittent calf compression and enoxaparin for thromboprophylaxis in total hip replacement. A pilot study. Int Orthop. 1996;20(6):367-369. [pmid: 9049766].
15 Warwick D, Harrison J, Whitehouse S, Mitchelmore A, Thornton M. A randomised comparison of a foot pump and low-molecular-weight heparin in the prevention of deep-vein thrombosis after total knee replacement. J Bone Joint Surg Br. 2002;84(3):344-350. [pmid: 12002490].
16 Warwick D, Harrison J, Glew D, Mitchelmore A, Peters TJ, Donovan J. Comparison of the use of a foot pump with the use of low-molecular-weight heparin for the prevention of deep-vein thrombosis after total hip replacement. A prospective, randomized trial. J Bone Joint Surg Am. 1998;80(8):1158-1166. [pmid: 9730125].
17 Windisch C, Kolb W, Kolb K, Grutzner P, Venbrocks R, Anders J. Pneumatic compression with foot pumps facilitates early postoperative mobilisation in total knee arthroplasty. Int Orthop. 2011;35(7):995-1000. [pmid: 20652250].
18 Wood KB, Kos PB, Abnet JK, Ista C. Prevention of deep-vein thrombosis after major spinal surgery: a comparison study of external devices. J Spinal Disord. 1997;10(3):209-214. [pmid: 9213276].
19 Bockheim HM, McAllen KJ, Baker R, Barletta JF. Mechanical prophylaxis to prevent venous thromboembolism in surgical patients: a prospective trial evaluating compliance. J Crit Care. 2009;24(2):192-196. [pmid: 19327952].
20 Proctor MC, Greenfield LJ, Wakefield TW, Zajkowski PJ. A clinical comparison of pneumatic compression devices: the basis for selection. J Vasc Surg. 2001;34(3):459-463. discussion 463-454. [pmid: 11533598].
21 Robertson KA, Bertot AJ, Wolfe MW, Barrack RL. Patient compliance and satisfaction with mechanical devices for preventing deep venous thrombosis after joint replacement. J South Orthop Assoc. 2000;9(3):182-186. [pmid: 12135300].