# SEARCH STRATEGIES

## Database: MEDLINE (via PubMed)

Search date: 10/30/14

Set # | Search Terms | Results
#1 | Search “venous thrombosis”[MeSH Terms] OR venous thrombo*[tiab] OR deep-venous thrombo*[tiab] OR deep vein thrombo*[tiab] OR deep-vein thrombo*[tiab] OR phlebothrombo*[tiab] OR “Thromboembolism”[Mesh:NoExp] OR “thrombophlebitis”[tiab] OR thromboemboli*[tiab] OR “Venous Thromboembolism”[Mesh] OR venothrombolic event*[tiab] OR “VTEs”[tiab] OR “VTE”[tiab] OR “Thrombosis”[Mesh:NoExp] OR “Thrombosis”[tiab] | 187,263
#2 | Search “intermittent pneumatic compression devices”[MeSH Terms] OR compression device*[tiab] OR “intermittent compression”[tiab] OR “intermittent pneumatic”[tiab] OR foot pump*[tiab] OR foot-pump*[tiab] OR “Gravity Suits”[Mesh] OR “compression garment”[tiab] OR “inflatable garment”[tiab] OR “pneumatic pump”[tiab] OR “gradient pressure”[tiab] OR “Pneumatic compressor”[tiab] OR “pneumatic appliance”[tiab] OR “WizAIR”[tiab] OR “Flowtron”[tiab] OR “Phlebo”[tiab] OR “Kendall”[tiab] OR air massage*[tiab] OR “A-V impulse system”[tiab] OR “VenaFlow”[tiab] OR “Jobst”[tiab] OR “ArtAssist”[tiab] OR “Plexipulse”[tiab] OR “SC-2004 Sequential Circulator PCD”[tiab] OR “Walkcare”[tiab] OR “Venodyne”[tiab] OR “IPC”[tiab] OR “PIC”[tiab] OR “EPIC”[tiab] OR “IPEC”[tiab] OR “Bandages”[Mesh:NoExp] OR “Assisted Circulation”[Mesh:NoExp] | 28,466
#3 | Search #1 AND #2 | 1923
#4 | Search #3 NOT (animals[mh] NOT humans[mh]) | 1879
#5 | #4 NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) Sort by: Author Filters: Publication date from 1995/01/01; English | 963

## Database: Embase

Search date: 10/30/14

Set # | Search Terms | Results
#1 | ‘vein thrombosis’/exp OR ‘thrombosis’/de OR thrombo*:ab,ti OR phlebothrombo*:ab,ti OR “venothrombolic event”:ab,ti OR “VTE”:ab,ti OR “VTEs”:ab,ti | 460,903
#2 | ‘intermittent pneumatic compression device’/exp OR “A-V Impulse System”:ab,ti OR “ArtAssist”:ab,ti OR “Flexitouch system”:ab,ti OR “FLOWTRON”:ab,ti OR “intermittent pneumatic compression devices”:ab,ti OR “Plexipulse”:ab,ti OR “pneumatic intermittent impulse device”:ab,ti OR “SC-2004 Sequential Circulator PCD”:ab,ti OR “Walkcare”:ab,ti OR ‘assisted circulation’/de OR ‘bandage’/de OR ‘mast suit’/exp OR ‘compression instrument’/de OR “compression device”:ti,ab OR “intermittent compression”:ti,ab OR “intermittent pneumatic”:ti,ab OR “foot pump”:ti,ab OR “foot-pumps”:ti,ab OR “foot-pump”:ti,ab OR “compression garment”:ti,ab OR “inflatable garment”:ti,ab OR “pneumatic pump”:ti,ab OR “gradient pressure”:ti,ab OR “Pneumatic compressor”:ti,ab OR “pneumatic appliance”:ti,ab OR “WizAIR”:ti,ab OR “Phlebo”:ti,ab OR “Kendall”:ti,ab OR “air massage”:ti,ab OR “air massages”:ti,ab OR “VenaFlow”:ti,ab OR “Jobst”:ti,ab OR “Venodyne”:ti,ab | 25,460
#3 | #1 AND #2 | 2519
#4 | #3 AND ([embase]/lim OR [embase classic]/lim) NOT [medline]/lim | 807
#5 | #4 NOT (‘case report’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) | 735
#6 | #5 AND [humans]/lim AND [english]/lim | 437
#7 | #6 AND [1995-2014]/py | 425

## Database: CINAHL (Key Question 4 only)

Search date: 10/30/14

Set # | Search Terms | Results
S1 | (MH “Compression Garments”) | 1634
S2 | (MH “Compression Therapy”) | 1673
S3 | (MH “Bandages and Dressings”) | 7649
S4 | TI ( “intermittent pneumatic compression device” or “A-V Impulse System” or “ArtAssist” or “Flexitouch system” or “FLOWTRON” or “intermittent pneumatic compression devices” or “Plexipulse” or “pneumatic intermittent impulse device” or “SC-2004 Sequential Circulator PCD” or “Walkcare” or “assisted circulation” or “bandage” or “compression instrument” or “compression device” or “intermittent compression” or “intermittent pneumatic” or “foot pump” or “foot-pumps” or “foot-pump” or “compression garment” or “inflatable garment” or “pneumatic pump” or “gradient pressure” or “Pneumatic compressor” or “pneumatic appliance” or “WizAIR” or “Phlebo” or “Kendall” or “air massage” or “air massages” or “VenaFlow” or “Jobst” or “Venodyne” ) OR AB ( “intermittent pneumatic compression device” or “A-V Impulse System” or “ArtAssist” or “Flexitouch system” or “FLOWTRON” or “intermittent pneumatic compression devices” or “Plexipulse” or “pneumatic intermittent impulse device” or “SC-2004 Sequential Circulator PCD” or “Walkcare” or “assisted circulation” or “bandage” or “compression instrument” or “compression device” or “intermittent compression” or “intermittent pneumatic” or “foot pump” or “foot-pumps” or “foot-pump” or “compression garment” or “inflatable garment” or “pneumatic pump” or “gradient pressure” or “Pneumatic compressor” or “pneumatic appliance” or “WizAIR” or “Phlebo” or “Kendall” or “air massage” or “air massages” or “VenaFlow” or “Jobst” or “Venodyne” ) | 1187
S5 | S1 OR S2 OR S3 OR S4 | 10,761
S6 | TI ( thrombo* or phlebothrombo* or “venothrombolic event” or “VTE” or “VTEs” ) OR AB ( thrombo* or phlebothrombo* or “venothrombolic event” or “VTE” or “VTEs” ) | 25,614
S7 | (MH “Venous Thrombosis+”) OR (MH “Thromboembolism+”) OR (MH “Thrombosis+”) | 21,952
S8 | S6 OR S7 | 36,538
S9 | S5 AND S8 | 841
S10 | S9 Limiters - English Language; Published Date: 19950101-20141231; Exclude MEDLINE records; Language: English; Search modes - Find all my search terms | 309
S11 | (MH “Prospective Studies+”) OR (MH “Cross Sectional Studies”) OR (MH “Quasi-Experimental Studies+”) OR (MH “Retrospective Design”) | 433,714
S12 | S10 AND S11 | 18

## Database: Cochrane CENTRAL

Search date: 10/30/14

Set # | Search Terms | Results
#1 | deep vein thrombosis:ti,ab,kw (Word variations have been searched) | 2205
#2 | deep vein thromboses:ti,ab,kw (Word variations have been searched) | 40
#3 | thrombo* or phlebothrombo* or “venothrombolic event” or “VTE” or “VTEs”:ti,ab,kw (Word variations have been searched) | 22,495
#4 | [or #1-#3] | 22,495
#5 | “intermittent pneumatic compression device” or “A-V Impulse System” or “ArtAssist” or “Flexitouch system” or “FLOWTRON” or “intermittent pneumatic compression devices” or “Plexipulse” or “pneumatic intermittent impulse device” or “SC-2004 Sequential Circulator PCD” or “Walkcare” or “assisted circulation” or “bandage” or “compression instrument” or “compression device” or “intermittent compression” or “intermittent pneumatic” or “foot pump” or “foot-pumps” or “foot-pump” or “compression garment” or “inflatable garment” or “pneumatic pump” or “gradient pressure” or “Pneumatic compressor” or “pneumatic appliance” or “WizAIR” or “Phlebo” or “Kendall” or “air massage” or “air massages” or “VenaFlow” or “Jobst” or “Venodyne”:ti,ab | 1984
#6 | [and #4-#5] Publication Year from 1995 to 2014, in Cochrane Reviews (Reviews and Protocols) and Trials | 205