# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Questions #1 and #2

We identified reports commissioned by AHRQ and the Robert Wood Johnson Foundation regarding how to best produce and disseminate public reports. Their conclusions about solutions for the design of public reports are three-fold. To make the information more relevant to what consumers already understand and care about, public reports should give an overall definition of quality, define the elements of quality and use them as the reporting categories, and include information about the sponsor and methods. To make it easy for consumers to understand and use the comparative information summarize, interpret, highlight meaning, narrow options and help bring the information together in a choice by using summary measures and meaningful symbols. Finally, testing reports with consumers during development will help identify areas of misunderstanding and assess users' perceptions of the report's value.

### Key Question #3

Conclusions from the studies of public reporting are mixed, but most studies found the use of publicly available data to be modest at best. Although consumers may show interest in public reports, in most cases interest does not seem to translate into actual use. The studies that do show use suggest that consumers may avoid low performers, but higher performers may not reap comparable positive benefits of public reporting.

### Key Question #4

We identified relatively few new studies within our scope in the peer reviewed literature during the five years since the search was conducted for Fung et al. Two of the newly identified studies addressed the impact of reporting on quality improvement activities. Some empirical evidence and the conclusion of the prior review support the theory that public reporting stimulates quality improvement activities. Five new studies identified address a variety of outcomes (patient or consumer experience, obtaining performance targets, rates of caesarean and mortality) and four of the five are national studies. All five conclude that public reporting has a positive impact on quality or safety outcomes; however, the effect was small and two studies were time series studies in a single country, where all providers were subject to public reporting and the change, each could have been due to other changes that impacted all providers.

This small and varied amount of additional evidence is not sufficient to change the conclusion of the Fung et al. review that “the effect of public reporting on effectiveness, safety, and patient-centeredness remains uncertain.” However, the CHOP assessment from 2005 provides some encouragement that this may be changing.

## LIMITATIONS

The principal limitation to this review is the limited number of public reporting systems that have been subjected to critical published evaluations. Most of the published evidence about the effects of public reporting concern the Cardiac Surgery Reporting System in New York State (CSRS), the Consumer Assessment of Health Plans (CAHPS), and the Cleveland Health Quality Choice program (CHQC), which was abandoned after five years. Far more public reporting programs in America have not been evaluated compared with those that have. Findings from evaluations that have been conducted should be generalized very cautiously, if at all. There is also the possibility of publication bias: additional evaluations may have been conducted but the results are not easily available in the published, peer-viewed literature. Possible reasons include negative findings, the researcher never submitted findings to a journal due to lack of time/interest, and/or work was completed for a stakeholder who was not interested in journal publications. Other potentially relevant evaluations and studies probably exist, but cannot be identified and synthesized based on an examination of databases that are easily searchable. For example, entering “public reporting of quality information” into Google produces over 19,000,000 hits, a number that is impractical to review. Even using limited search terms produces tens of thousands of hits. We did incorporate a limited Google search, but did not identify any new studies in the top 30 hits.

## CONCLUSIONS

Even with these limitations, the evidence is consistent that most consumers do not know about or make little use of publicly available performance data when selecting health services providers. Attention to the summary point of designing performance reports and presentation and dissemination may more fully engage consumers. Yet, even without evidence that public reporting has had much effect via the “selection” pathway, evidence (albeit mixed) suggests that public reporting can still achieve some improvements in processes and outcomes of care by stimulating providers to change. In addition, public reporting furthers the VA's goal of transparency.

### Applicability of Findings to the VA Population

None of the evidence we identified studied VA public reporting systems or assessed Veterans' use of non-VA public reporting systems. Nevertheless, it is unlikely that most veterans currently use publicly available data on quality and safety in making choices. Experience from non-VA studies suggests the main way that public reporting improves quality and safety is by motivating individuals and organizations to change care delivery. The mechanisms for this motivation can be varied but seem to include both the desire to attract and maintain patients and the desire to be viewed positively by peers. Whether this same motivation holds true in a system such as the VA, which for many patients is a safety-net provider, is unknown. For veterans who do have a choice in health care providers, presenting VA and non-VA information in the same place and making it similar in content and format will be necessary in order to avoid making the cognitive burden of synthesizing the information too high such that it will not be used by veterans. It is not clear whether public reporting would stimulate future changes in a system such as the VA with a robust quality assessment and feedback system already in place.

## RECOMMENDATIONS FOR FUTURE RESEARCH

As VA pursues its transparency goals and continues to expand the quality and safety information made available to Veterans and other stakeholders, there is an opportunity to increase the impact of public reporting on the wellbeing of veterans and to contribute to the knowledge related to public reporting and quality improvement in health care.

Examples of specific questions that could be answered by appropriate research include:

1. What health care decisions do veterans and their families face, and what kinds of information needs do they have? How do they want to receive or access data about quality?
2. Are veterans aware of the VA's public reporting website? How often have they accessed the website? Do they understand the information being presented?
3. How well is VA's public reporting meeting Veteran needs?

Understanding this would help fashion transparency and public reporting efforts that provide the ‘right’ information at the ‘right’ time to the ‘right’ people. Key to achieving these goals may be the ability to tailor information to an individual, or to a subgroup of veterans. Health care decisions are personal, and generic information is unlikely to best provide what is wanted or needed. The combination of data, technology, and individualized information about potential health care service options and their implications presents the possibility of major improvements in public reporting.