# REFERENCES

1 Open Government Plan, June 2010. Prepared on Behalf of the Honorable Eric K. Shinsheki, Secretary. United States Department of Veterans Affairs. Washington, D.C. 2010:1-29.
2 VA Hospital Compare. November. 23. 2010. Available from: http://www.hospitalcompare.va.gov/.
3 Berwick DM, James B, Coye MJ. Connections between quality measurement and improvement. Med Care. 2003;41(1 Suppl):I30-8. [pmid: 12544814].
4 Hibbard JH, Stockard J, Tusler M. Hospital performance reports: impact on quality, market share, and reputation. Health Aff (Millwood). 2005;24(4):1150-60. [pmid: 16012155].
5 Fung CH, et al. Systematic review: the evidence that publishing patient care performance data improves quality of care. Ann Intern Med. 2008;148(2):111-23. [pmid: 18195336].
6 GRADE Working Group. Grading of Recommendations, Assessment, Development, and Evaluation. Available from: http://www.gradeworkinggroup.org/FAQ/index.htm.
7 Shea BJ, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
8 Marshall MN, et al. The public release of performance data - What do we expect to gain? A review of the evidence. Jama-Journal of the American Medical Association. 2000;283(14):1866-1874.
9 O'Neil S, Schurrer j, Simon S. Environmental Scan of Public Reporting Programs and Analysis for the National Quality Forum. 2010. Mathematica Policy Research. Washington, D.C.
10 Hibbard J, Sofaer S. Best practices in public reporting no. 1: how to effectively present health care performance data to consumers. June. 2010. Agency for Healthcare Research and Quality. Rockville, MD. AHRQ Publication No. 10-0082-EF.
11 Sofaer S, Hibbard J. Best practices in public reporting no. 2: Maximizing consumer understanding of public comparative quality reports: Effective use of explanatory information. June. 2010. Agency for Healthcare Research and Quality. Rockville, MD. AHRQ Publication No. 10-0082-1-EF.
12 Sofaer S, Hibbard J. Best practices in public reporting no. 3: How to maximize public awareness and use of comparative quality reports through effective promotion and dissemination strategies. June. 2010. Agency for Healthcare Research and Quality. Rockville, MD. AHRQ Publication No. 10-0082-2-EF.
13 Overview: AHRQ Learning Network for Chartered Value Exchanges. September. 2010. Available from: http://www.ahrq.gov/qual/value/lncveover.htm.
14 Consumer Decision Points in Accessing Comparative Health Information. 2010. Robert Wood Johnson Foundation. Princeton, NJ.
15 How to display comparative information that people can understand and use. 2010. Robert Wood Johnson Foundation. Princeton, NJ.
16 About Aligning Forces for Quality. 2011. Available from: http://www.rwjf.org/qualityequality/af4q/about.jsp.
17 Language to Use in Public Reporting About Hospital Care. 2011. Available from: http://www.rwjf.org/qualityequality/product.jsp?id=71839.
18 How to Describe the Health and Community Context for Comparative Performance Reports. 2011. Available from: http://www.rwjf.org/qualityequality/product.jsp?id=71842.
19 Communicating with Physicians about Performance Measurement. 2011. Available from: http://www.rwjf.org/qualityequality/product.jsp?id=71803.
20 Mazor KM, Dodd KS, Kunches L. Communicating Hospital Infection Data to the Public: A Study of Consumer Responses and Preferences. American Journal of Medical Quality. 2009;24(2):108-115. [pmid: 19237552].
21 Mazor KM, Dodd KS. A Qualitative Study of Consumers' Views on Public Reporting of Health Care-Associated Infections. American Journal of Medical Quality. 2009;24(5):412-418. [pmid: 19525369].
22 Richard SA, Rawal S, Martin DK. Patients' views about cardiac report cards: A qualitative study. Canadian Journal of Cardiology. 2005;21(11):943-947. [pmid: 16239978].
23 Carman KL. Improving quality information in a consumer-driven era: showing the differences is crucial to informed consumer choice. Presentation at the 10th National CAHPS User Group Meeting. 2006. Baltimore, MD.
24 Garcia-Lacalle J. A bed too far - The implementation of freedom of choice policy in the NHS. Health Policy. 2008;87(1):31-40. [pmid: 18078681].
25 Geraedts M, Schwartze D, Molzahn T. Hospital quality reports in Germany: patient and physician opinion of the reported quality indicators. Bmc Health Services Research. 2007;7.
26 Faber M, et al. Public reporting in health care: how do consumers use quality-of-care information? A systematic review. Med Care. 2009;47(1):1-8. [pmid: 19106724].
27 Dixon A, Greene J, Hibbard J. Do consumer-directed health plans drive change in enrollees' health care behavior?. Health Affairs. 2008;27(4):1120-1131. [pmid: 18607046].
28 Peters E, et al. Less is more in presenting quality information to consumers. Med Care Res Rev. 2007;64:169-190. [pmid: 17406019].
29 Jha AK, Epstein AM. The predictive accuracy of the New York State coronary artery bypass surgery report-card system. Health Aff (Millwood). 2006;25(3):844-55. [pmid: 16684751].
30 Jin GZ, Sorensen AT. Information and consumer choice: the value of publicized health plan ratings. J Health Econ. 2006;25(2):248-75. [pmid: 16107284].
31 Uhrig JD, et al. Do content and format affect older consumers' use of comparative information in a Medicare health plan choice? Results from a controlled experiment. Med Care Res Rev. 2006;63(6):701-18. [pmid: 17099122].
32 Cutler DA, Huckman RS, Landrum MB. The role of information in medical markets: An analysis of publicly reported outcomes in cardiac surgery. American Economic Review. 2004;94(2):342-346.
33 Romano PS, Zhou H. Do well-publicized risk-adjusted outcomes reports affect hospital volume?. Med Care. 2004;42(4):367-77. [pmid: 15076814].
34 Baker DW, et al. The effect of publicly reporting hospital performance on market share and risk-adjusted mortality at high-mortality hospitals. Med Care. 2003;41(6):729-40. [pmid: 12773839].
35 Beaulieu ND. Quality information and consumer health plan choices. J Health Econ. 2002;21(1):43-63. [pmid: 11845925].
36 Chassin MR. Achieving and sustaining improved quality: lessons from New York State and cardiac surgery. Health Aff (Millwood). 2002;21(4):40-51. [pmid: 12117152].
37 Farley DO, et al. Effects of CAHPS health plan performance information on plan choices by New Jersey Medicaid beneficiaries. Health Serv Res. 2002;37(4):985-1007. [pmid: 12236394].
38 Farley DO, et al. Effect of CAHPS performance information on health plan choices by Iowa Medicaid beneficiaries. Med Care Res Rev. 2002;59(3):319-36. [pmid: 12205831].
39 Harris KM. Can high quality overcome consumer resistance to restricted provider access? Evidence from a health plan choice experiment. Health Serv Res. 2002;37(3):551-71. [pmid: 12132595].
40 Harris K, Schultz J, Feldman R. Measuring consumer perceptions of quality differences among competing health benefit plans. Journal of Health Economics. 2002;21(1):1-17. [pmid: 11845919].
41 Hibbard JH, et al. Strategies for reporting health plan performance information to consumers: evidence from controlled studies. Health Serv Res. 2002;37(2):291-313. [pmid: 12035995].
42 Hibbard JH, et al. The impact of a CAHPS report on employee knowledge, beliefs, and decisions. Med Care Res Rev. 2002;59(1):104-16. [pmid: 11877876].
43 Scanlon DP, et al. The impact of healthplan report cards on managed care enrollment. J Health Econ. 2002;21:19-41. [pmid: 11845924].
44 Uhrig JD, Short PF. Testing the effect of quality reports on the health plan choices of Medicare beneficiaries. Inquiry. 2002;39(4):355-71. [pmid: 12638711].
45 Wedig GJ, Tai-Seale M. The effect of report cards on consumer choice in the health insurance market. J Health Econ. 2002;21(6):1031-48. [pmid: 12475124].
46 Hibbard JH, et al. Making health care quality reports easier to use. Jt Comm J Qual Improv. 2001;27(11):591-604. [pmid: 11708039].
47 Schoenbaum M, et al. Health plan choice and information about out-of-pocket costs: an experimental analysis. Inquiry. 2001;38(1):35-48. [pmid: 11381720].
48 Hibbard JH, et al. Increasing the impact of health plan report cards by addressing consumers' concerns. Health Aff (Millwood). 2000;19(5):138-43. [pmid: 10992661].
49 Spranca M, et al. Do consumer reports of health plan quality affect health plan selection?. Health Serv Res. 2000;35(5 Pt 1):933-47. [pmid: 11130805].
50 Knutson DJ, et al. Impact of report cards on employees: a natural experiment. Health Care Financ Rev. 1998;20(1):5-27. [pmid: 10387425].
51 Mukamel DB, Mushlin AI. Quality of care information makes a difference: an analysis of market share and price changes after publication of the New York State Cardiac Surgery Mortality Reports. Med Care. 1998;36(7):945-54. [pmid: 9674613].
52 Mennemeyer ST, Morrisey MA, Howard LZ. Death and reputation: how consumers acted upon HCFA mortality information. Inquiry. 1997;34(2):117-28. [pmid: 9256817].
53 Hibbard JH, Sofaer S, Jewett JJ. Condition-specific performance information: assessing salience, comprehension, and approaches for communicating quality. Health Care Financ Rev. 1996;18(1):95-109. [pmid: 10165040].
54 Hannan EL, et al. New York State's Cardiac Surgery Reporting System: four years later. Ann Thorac Surg. 1994;58(6):1852-7. [pmid: 7979781].
55 Vladeck BC, et al. Consumers and hospital use: the HCFA “death list”. Health Aff (Millwood). 1988;7(1):122-5. [pmid: 3360387].
56 Rainwater JA, et al. Evaluation of California's HMO report card: A report for the California Office of the Patient Advocate. 2005. UCD Center for Health Services Research in Primary Care. Davis, CA.
57 Wang J, et al. Do bad report cards have consequences? Impacts of publicly reported provider quality information on the CABG market in Pennsylvania. NBER Working Paper Series. 2010:1-48.
58 Hibbard JH, Stockard J, Tusler M. Does publicizing hospital performance stimulate quality improvement efforts?. Health Aff (Millwood). 2003;22(2):84-94. [pmid: 12674410].
59 Dziuban SW Jr, et al. How a New York cardiac surgery program uses outcomes data. Ann Thorac Surg. 1994;58(6):1871-6. [pmid: 7979785].
60 Bentley JM, Nash DB. How Pennsylvania hospitals have responded to publicly released reports on coronary artery bypass graft surgery. Jt Comm J Qual Improv. 1998;24(1):40-9. [pmid: 9494873].
61 Tu JV, Cameron C. Impact of an acute myocardial infarction report card in Ontario, Canada. Int J Qual Health Care. 2003;15(2):131-7. [pmid: 12705706].
62 Rosenthal GE, et al. Using hospital performance data in quality improvement: the Cleveland Health Quality Choice experience. Jt Comm J Qual Improv. 1998;24(7):347-60. [pmid: 9689568].
63 Longo DR, et al. Consumer reports in health care. Do they make a difference in patient care?. JAMA. 1997;278(19):1579-84. [pmid: 9370503].
64 Mannion R, Davies H, Marshall M. Impact of star performance ratings in English acute hospital trusts. J Health Serv Res Policy. 2005;10(1):18-24. [pmid: 15667700].
65 Luce JM, et al. Use of risk-adjusted outcome data for quality improvement by public hospitals. West J Med. 1996;164(5):410-4. [pmid: 8686297].
66 Rainwater JA, Romano PS, Antonius DM. The California Hospital Outcomes Project: how useful is California's report card for quality improvement?. Jt Comm J Qual Improv. 1998;24(1):31-9. [pmid: 9494872].
67 Kim CY, Ko SK, Kim KY. Are league tables controlling epidemic of caesarean sections in South Korea?. Bjog-an International Journal of Obstetrics and Gynaecology. 2005;112(5):607-611. [pmid: 15842285].
68 Elliott MN, et al. Hospital Survey Shows Improvements In Patient Experience. Health Affairs. 2010;29(11):2061-2067. [pmid: 21041749].
69 Hendriks M, et al. Dutch healthcare reform: did it result in performance improvement of health plans? A comparison of consumer experiences over time. Bmc Health Services Research. 2009;9.
70 Bevan G, Hamblin R. Hitting and missing targets by ambulance services for emergency calls: effects of different systems of performance measurement within the UK. Journal of the Royal Statistical Society Series a-Statistics in Society. 2009;172:161-190.
71 Hannan EL, et al. Improving the outcomes of coronary artery bypass surgery in New York State. JAMA. 1994;271(10):761-6. [pmid: 8114213].
72 Peterson ED, et al. The effects of New York's bypass surgery provider profiling on access to care and patient outcomes in the elderly. J Am Coll Cardiol. 1998;32(4):993-9. [pmid: 9768723].
73 Ghali WA, et al. Statewide quality improvement initiatives and mortality after cardiac surgery. JAMA. 1997;277(5):379-82. [pmid: 9010169].
74 Moscucci M, et al. Public reporting and case selection for percutaneous coronary interventions: an analysis from two large multicenter percutaneous coronary intervention databases. J Am Coll Cardiol. 2005;45(11):1759-65. [pmid: 15936602].
75 Omoigui NA, et al. Outmigration for coronary bypass surgery in an era of public dissemination of clinical outcomes. Circulation. 1996;93(1):27-33. [pmid: 8616936].
76 Dranove D, et al. Is more information better? The effects of “report cards” on health care providers. Journal of Political Economy. 2003;111:555-88.
77 Rosenthal GE, Quinn L, Harper DL. Declines in hospital mortality associated with a regional initiative to measure hospital performance. Am J Med Qual. 1997;12(2):103-12. [pmid: 9161057].
78 Clough JD, et al. Lack of relationship between the Cleveland Health Quality Choice project and decreased inpatient mortality in Cleveland. Am J Med Qual. 2002;17(2):47-55. [pmid: 11941994].
79 Baker DW, et al. Mortality trends during a program that publicly reported hospital performance. Med Care. 2002;40(10):879-90. [pmid: 12395022].
80 Bost JE. Managed care organizations publicly reporting three years of HEDIS measures. Manag Care Interface. 2001;14(9):50-4. [pmid: 11569305].
81 McCormick D, et al. Relationship between low quality-of-care scores and HMOs' subsequent public disclosure of quality-of-care scores. JAMA. 2002;288(12):1484-90. [pmid: 12243635].