# METHODS

## TOPIC DEVELOPMENT

This project was nominated by the Transparency Initiative Lead in the Office of Quality and Performance, Maris Norwood.

The final key questions are:

Key Question #1 What is known about the most effective way of displaying quality and safety information, comparative data about health system structure, services, and performance so that it is understandable?
Key Question #2 How do patients prefer to receive or access this information?
Key Question #3 What is the evidence that patients or their families use publicly reported quality and safety information to make informed health care decisions?
Key Question #4 What is the evidence that public reporting of quality and safety information leads to improved quality or safety?

## SEARCH STRATEGY

The topic of public reporting has been reviewed several times, most recently published in 2008 by Fung and colleagues with a literature review current through 2006. We used science citation searches of high-profile reviews and seminal articles as our means to identify new material, in addition to the existing material in the most recent review by Fung and colleagues (Appendix A). We searched Web of Science, with the sub-databases Science (SCI-EXPANDED), Social Science (SSCI), Arts and Humanities (A&HCI), and the Science and Social Sciences Proceedings (CPCI-S C CPCI-SSH) using standard search terms. We searched from the original publication date of the high profile review on seminal articles through July 2011. We chose to keep the publication date criteria open-ended, so no start date was set. We limited the search to articles published in English since we judged that for these key questions, context mattered; for the first two questions, we restricted the articles to those presenting data on English-speaking countries. We also conducted a web search by entering the terms “public reporting of quality information healthcare” into Google and taking the top 30 hits.

## STUDY SELECTION

Two reviewers assessed for relevance the abstracts of citations identified from literature searches. Full-text articles of potentially relevant abstracts were retrieved for further review. Each article was reviewed using the eligibility criteria in Appendix B.

Specific exclusion criteria were as follows:

1. Because VA is only anticipating public reporting for facilities, we excluded studies regarding quality and safety information about nursing homes, physicians or other individual providers
2. No key question addressed, or serving background purposes only
3. Non-systematic review, commentary or news, other article with no original data

## DATA ABSTRACTION

We abstracted the following data for each included study: study objective, subject of public reporting, whether the article discusses public reporting of hospital or health plan data, location, sample, study design, design rating, key findings, and global rating. (All of the data appear in the evidence tables in Appendix C-E)

## QUALITY ASSESSMENT

We assessed the quality of all included studies using criteria developed by Fung and colleagues in order to facilitate the synthesis of results.5 We replicated the criteria used in this review to evaluate study design and assign global rating. The criteria ranked study design based on four categories, with four stars indicating the strongest design (in general randomized or experimental studies), and one star representing the weakest. The global rating system was modeled after the Grading of Recommendations, Assessment, Development, and Evaluation (GRADE)system,6 and studies were ranked on whether they should carry great (highest score: 3), moderate (2), or little (1) weight when considering the strength of evidence. The global score takes the study design ranking into account, as well as “penetration of report card use (adherence), dose-response gradient, precision and validity of outcomes, and uncertainty about direction of the results.” Systematic reviews were assessed using the AMSTAR grading criteria7 (see Appendix F for details of all criteria).

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by key question. We analyzed studies to compare their characteristics, methods, and findings. We summarized findings for each key question and drew conclusions based on qualitative synthesis of the findings.

## PEER REVIEW

A draft version of this report was reviewed by seven technical experts as well as clinical leadership. Their comments and our responses are presented in Appendix G.