# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Peer Review Comments | Comment | Response
Scope | Thought the scope was too small. The literature in this area is pretty scant and did not need an ESP to tell us that. Would have expanded review to no just patients but organizations, VSO, other health care systems and other federal agencies | The scope was provided to us by the co-sponsor and is not something we can choose now.
Scope | On pages 17 through 19 two long numbered lists are provided and referenced, but it's not clear if the entire lists are quoted verbatim from the original source. (This should be made clear if it is verbatim.) | These are not quoted verbatim, but rather summarized from the original report, which we now indicate.
Scope | This is a superb and comprehensive review, but may short-change both public reporting and the VA, at least according to one authoritative published opinion. Lucian Leape recently concluded that public reporting was “So far, the most powerful method for reducing preventable injuries”, and he went on to cite the VA's own NISQUIP program as the most shining example. (Transparency and public reporting are essential for a safe health care system. LL Leape. The Commonwealth Fund Publication 1381, Vol 4: “Perspectives on Health Reform”. March 2010. Accepting that data showing that public reporting improves safety may not yet be strong, Leape's comments point out that this approach seems at least to have more potential than many of the alternatives (regulation, alignment of incentives, accreditation). I'd like to see this perspective mentioned in the discussion. I'd also like to see a brief data summary regarding studies that have looked at VA programs specifically. | This comment quotes Lucian Leape as stating public reporting is a “powerful method for reducing preventative injuries.” We would agree that public reporting consistently influences providers to meet the criteria being reported. However NSQUIP cannot be used as an example, since NSQUIP is not publicly reported, at least not at the time of the studies documenting improvements due to NSQUIP.
Scope | 2^nd^ paragraph, sentence beginning “Public reporting also…may only be known by providers” – awkward sentence | We have rewritten for clarity.
Scope | 2nd full paragraph re: hospitals in South Korea – unclear why data from non-English speaking country was included for this key question but not others. | We restricted KQ 1&2 to English speaking countries only since we judged that the context of the country mattered for questions about “how to most effectively display information” and “how do patients prefer to receive this information?” In other words, we thought data about how patients in non-English speaking countries such as Korea and the Netherlands would have limited relevance to the US. However, for KQ 3&4, about what effects public reporting has, we did not judge country context to be as important and therefore included studies from other countries.
Scope | P. 26, 3rd full paragraph, last sentence – should be “difference was no longer significant” rather than “difference was no long significant”. P. 26, 4th full paragraph, 1st sentence – should end with “selection of patients for procedures” instead of “patient”. P. 29, Key Questions 1 and 2, last sentence – “assess” is misspelled. | Typo's are corrected
Scope | P. 30, Acceptability of Findings to the VA Population, second sentence – Would suggest adding: “It is not clear whether public reporting would stimulate further changes in a system such as VA with a robust quality assessment and feedback system already in place.” General comment – “Veteran” is sometimes capitalized in document and sometimes lowercase. | Text has been added.
Scope | Methods: the discussion about excluding Fung articles, then adding them in, is confusing. Exclusion criteria should only focus on what is fully excluded from the synthesis. | This section has been updated for clarity.
Scope | Of the 11 articles “rejected” because they focused onn individual providers, were there any global insights that impact questions 2 or 3? Are the trends/insights any different from those for hospitals/facilities? | We did not look into detail at the studies on individual providers. The Fung review did include such studies and concluded that in the few studies found results were mixed in the effect on selection of provider and un-clinical outcomes and unintended consequences; no studies were identified as quality improvement activities (11 studies were identified for hospitals).
Scope | Add a section called Recommendations for VA. The section on applicability to the VA population does not get at issues specific to operations/implementation of public reporting of VA data. The Transparency initiative, for example, would benefit from learning more about Aligning Forces for Quality and their experience with providing community-level data to the public. | “Recommendations for VA” is not a heading in our report template. Rather our report provides evidence for a VA policymaker to make recommendations.
Scope | Seems like a tepid conclusion in light of the actual studies. It seems like there is very little evidence that patients and families use reports. Any impact on market share or volume may, in fact, involve decisions made by payers, or the influence of other factors (like loss of accreditation, program closures, etc). | We agree that there is very little evidence that patients and families use reports. We think our existing statement that use is “moderate at best” accurately conveys this.
Scope | Consumer vs. Patient. There is some variation in use of the term patient and consumer. Both terms are important, yet will have different conceptual views by readers. To address this issue, it might be valuable to have statements early in the document that patient is meant to convey the Veteran and primary target of VA-related public data, and that consumer is a commonly-used term in discussion about public reporting of data. In general, for the purposes of the report, consider them interchangeable (keep in mind that consumer can include family members and informal caregivers, so is a broader and more inclusive term). Then pick one and use that for the rest of the report. | We have added these terms to the report.
Scope | Definition of Provider. There are several uses of the term “provider” – from an individual doctor or clinician, to a hospital or clinic. This will be confusing for readers. Suggest using the term provider to refer to clinicians, and facility/health care provider spelled out for the latter. | Definition of provider - We disagree with this distinction and use of “provider” in the broad sense, which can be an individual provider (authors of those are excluded from the report) and also hospitals and health plans.
Scope | Topic development: is the Office of Quality and Performance a VA or VHA entity? | It is a VHA entity.
Scope | What were the Fung criteria (could state them, rather than relegate to Appendix). | Language has been modified.
Scope | Literature flow: match the numbers in the narrative with the numbers in the diagram (3 or 6 studies from content experts??) | Numbers are now in agreement.
Scope | Discussion about prior reviews is under Literature Flow. Consider a separate heading, such as Prior Review. | We have added this subheading.
Scope | Figure 2: what do circles numbered 1 and 2 represent? The “one mention” and “two mentions” must be the explanation…but it's not immediately clear to the reader. | We have revised the legend for clarity.
Scope | Key Question #1: why non-U.S. studies taken out? The comment about “particularly sensitive to context” makes the assumption that a person in Germany who gets health data is very different than a person in New York. | The cultural context here is around consumerism. The USA is considered a consumerist society, whereas all European countries have not been, although are becoming more so in the past 10 years.
Scope | Key Question #2: maybe I missed this, but I didn't see much discussion about how patients want to receive or access this information… | This section included all the data and recommendations that were in the Hibbard & Sofaer and the RWJ reports, there is nothing more about this topic that we can include.
Scope | Key Question #3, evidence from systematic review by Fung: Paragraph about the two pathways, and “change pathway” is confusing. | We have included a figure to better illustrate this.
Scope | Impact on Clinical Outcomes: prior discussion excluded non-U.S. studies, and this section discusses S. Korean and Dutch studies; this is confusing (see #12 – consider all non-U.S. studies | We have now excluded non-US studies. Still need to check with AT.
Scope | Interesting items in Limitations discussion – why was the CHQC program abandoned? Why was the CHOP report not part of this review (only because it wasn't in a peer review journal?) | We did not know why the CHOP was abandoned, that was not in the scope. We have added the newer CHOP report as part of our revision to add relevant evidence identified via internet searches.
Scope | Future research. Given the results of the report, there seem to be more research questions than those proposed. Was there any data about how consumers want to receive/access data? This is an important question that could be study variations in how the data is displayed is important, as well as credibility of the data, trust in the “deliverer” of the data (e.g. government). There are studies on numeracy and literacy and how to present data, although not specifically on publically reported data. | We have added this to the search question.
Search Related | Since there was very little in national work might have been interesting to also look at web sites and high quality blogs? Understand peer review is the best but if the data is not there need to look other places | This is a good suggestion and we have now incorporated a web search into the report. We added the Google search.
Search Related | Need large scope of review, maybe look more at social media and web info and not just published standard journals | This is a good suggestion and we have now incorporated a web search into the report. We added the Google search.
Search Related | If I were responsible for it the main thing I would want checked is the Google search mentioned above to see if the first few dozen “hits” identify any studies that should be added. | This is a good suggestion and we have now incorporated a web search into the report. We added the Google search.
Search Related | On page 30 the authors write that “public reporting of quality information” produces over 19,000,000 hits, but when the text is in quotes, it actually results in only 18,100 hits, and when the word “healthcare” is added separately to the search, then the number drops to 17,500, which is still a high number – but the first page of links look highly relevant to the study. Since I don't know which studies were excluded in Figure 1 there's no way to tell that the 22 new studies included in the report are the complete set of useful studies. | We have now incorporated a web search, but limited to the top 30 hits.
Database | The search methodology is described only briefly and incompletely. The methods say that the literature search was done “using standard search terms” and Appendix A, which is cited as the place to look for clarification, lists only a few author searches. This report would benefit from a comprehensive description of the search strategy, so that it can be checked and repeated in the future. If the exact terms were used as in the Fung report, that should be stated, or how the terms here differed. | Appendix A lists all the search terms and databases searched.
Database | Search strategy does not include search terms (would be helpful to see). | Appendix A lists all the search terms and databases searched.
Database | No terms for search presented (maybe this will be an appendix?) | The research terms and databases are in the appendix.
Nursing Home | Given the VA's provision of nursing home care, it would be preferable to have include nursing home care.
Nursing Home | The objectives, scope, and methods for this review are clearly described, but I am not certain why the review excluded published information about public reporting of nursing homes, physicians or individual providers. Certainly, the VA statement of transparency does not preclude this, and while present plans have implemented publication of facility level quality information there is great interest and expectancies that the transparency will spread. The review would have far more useful if these areas were INCLUDED (since they represent future needs rather than retrospective ) E.G. Having put up the website, now we pay a reviewer to identify how we should have done it (better late than never) , failure to include provider and nursing homes means we will always be chasing our tails. | Nursing homes and individual providers were not included in our scope as provided to us by central office.
Nursing Home | Study Selection #2, “nursing homes” – Since VA provides nursing home care, I would have liked to see this included | Nursing homes were not included in the scope provided to us.
Nursing Home | Scope is reasonably presented; however, the rationale for not including nursing homes and individual providers makes no sense. The key questions are not VA - specific, and if there is important information about the display of information or consumer use of information in decision-making, it would be of value here. | Nursing homes and individual providers were not included in our scope as provided to us by central office.
Nursing Home | Do any of the studies mention how hospital staff used the reports? Perhaps “internal transparency” can motivate quality improvement as much as external reporting. (Shame being, perhaps, an even greater motivator than money). | We did not look at “internal transparency” or reporting back to providers but not the public. The one study that directly assessed this question reported more quality improvement activity with public reporting.
Nursing Home | It is worth asking the question “what is missing”. For instance, pure public reporting, without any other organized effort to address poor performance or ensure accountability, may simply be “information noise”. On the other hand, if poor performers faced loss of accreditation, loss of business, or other penalties, they may be more likely to take action. It would be useful to know if any of the studies combined such managerial interventions with public reporting. | We did not assess the existence of managerial interventions, but think those can be assumed to exist, since without them plan and facility performance would be unlikely to change.
Nursing Home | Study selection: Need better rationale than “VA public reporting for facilities” for not including individual provider and nursing home data studies. The key questions are not VA specific, so it would be ideal to add these in. | The scope was given to us by central office and this is the rational they gave us.
Recommendations | Not clear how cites 10-12, 14-15 fit into an evidence review with the stated inclusion criteria. These seem more like suggestions/recommendations from a non-systematic review and seem much different than studies such as cites 37-39, for example. | The article and RWJ reports on public reporting are included because they are recommendations from high profile organizations made by experts and based in the evidence that is available. It seemed to us that our report would seem incomplete if it were missing these two key reports.
Recommendations | Can you be more precise how Hibbard and Sofaer arrived at their conclusions? It will be essential to know if these recommendations are based on “expert consensus” versus empirical evidence, and what exactly the nature of the evidence is (e.g., user acceptability testing – what types of users, how was testing done, etc) | The Hibbard and Sofaer reports are their recommendations, based on the available evidence, which was somewhat thin. Some of their evidence was usability testing. We judged the Hibbard & Sofaer and the RWJ recommendations to represent the best available blend of evidence and opinion.
Recommendations | Key Question #1 and #2 this section is well written and quite interesting to read. However, it seems like a summary of global recommendations from a few specific papers (Hibbard; Mazor) and less like a synthesis of data. How were these recommendations developed? What type of research was conducted to support the variety of comments and suggestions? While the literature is not large, it might be valuable to provide example of studies behind the suggestions.
Update Searches | Is it possible to do a quick check, using the same search terms, for any new articles published since January 2011? | We have preformed and update search though August 2011 and incorporated the one new study meeting the inclusion criteria (N=1).
Update Searches | Some of the newer reporting systems, such as CMS' Hospital Compare and the RWJ AF4Q pilots, are relatively recent. Hence, my earlier comment that we conduct a “quick peak” at literature published since Jan 2011. | We have done an update search, however, the one study meeting inclusion criteria was not about Hospital Compare or RWJ AF4Q.
Evidence & Summary | Quality of Evidence: the title suggests quality of the studies (“quality of evidence”); narrative is about impact on quality improvement efforts. | The narrative is meant to explain why the quality of evidence for these studies is generally low, namely why one study did a direct comparison.
Evidence & Summary | It would be good to restate or list what the Key Questions are before addressing them. | We have now restated the key questions in the executive summary.
Evidence & Summary | Summary: Consider repeating the Questions above each summary. | We have added this.