# CRITERIA USED IN QUALITY ASSESSMENT

Fung and Colleagues' Grading Criteria for Included Studies

Study design ratings:

- 4 stars indicate a randomized trial or experimental trial;
- 3 stars indicate a controlled trial, pre-post trial with control (controlled before-after trial);
- 2 stars indicate a pre-post without control, observational cohort study without multivariable adjustment, cross-sectional study without multivariable adjustment, analysis of time trends without control, or well-designed qualitative study; and
- 1 star indicates a case series, other qualitative study, or survey (descriptive) study.

Global ratings:

- 3 indicates great weight in the stratum's body of evidence;
- 2 indicates moderate weight; and
- 1 indicates little weight.

AMSTAR Grading Criteria for Systematic Reviews