# EVIDENCE TABLES FOR KEY QUESTION #3

Author, Year (ID) | Objective | Subject of public reporting; Hospital/Health plan; Location | Sample | Design Type | Design Rating; Global Rating | Key Findings
Articles from Fung and colleagues
Farley, 2002^37^ | To assess effects of providing CAHPS information on plan choices | CAHPS; Health plan; New Jersey | HMO Medical Plans in New Jersey; Medicaid beneficiaries (1998) | Randomized controlled trial | 4;3 | No effect on HMO choices overall; Participants who read the report card and did not select the dominant HMO chose the HMO with higher CAHPS scores.
Farley, 2002^38^ | To assess effects of providing CAHPS information on plan choices | CAHPS; Health plan; Iowa | HMO Medical Plans in Iowa; Medicaid Beneficiaries (2000) | Randomized controlled trial | 4;2 | No effect on HMO choices overall
Spranca, 2000^49^ | To assess effects of providing CAHPS information about hypothetical health plans on plan choices | Hypothetical plans; Health plan; Los Angeles | Hypothetical plans in laboratory setting; adults with private insurance | Experimental study | 4;2 | When plans had high CAHPS ratings, participants were willing to enroll in less expensive plans that restrict services
Harris, 2002^39^ | To investigate the impact of expert-assessed and consumer-assessed quality ratings on willingness to enroll in hypothetical health plans that restrict provider access | Hypothetical plans; Health plan; Los Angeles | Laboratory setting; Privately insured adults (2000) | Experimental study | 4;2 | Provision of report cards with information about quality of health plan reduced importance of provider network features
Beaulieu, 2002^35^ | To assess effects of providing health plan performance data (HEDIS measures, patient satisfaction) on consumers' enrollment decisions | HEDIS; Health plan; Harvard University | Private health plans available to Harvard employees; Harvard employees (1994 to 1997) | Observational cohort | 3;2 | Provision of quality information had a small but statistically significant effect on health plan choices.
Wedig, 2002^45^ | To assess effects of providing quality ratings from the Federal Employee Health Benefit guide on consumers' plan choices | Federal Employee Health Benefit guide; Health plan; U.S. | Private health plans available to federal employees; Federal employees with single person HMO coverage residing in counties with 5 or fewer unique plans (1995 to 1996) | Observational cohort | 3;2 | Dissemination of report cards influenced plan selection. Employees were more likely to select plans with better quality ratings.
Jin, 2005^30^ | To assess effects of providing quality ratings from the Federal Employee Health Benefit guide on plan choices | Federal Employee Health Benefit guide; Health plan; U.S. | Private health plans serving federal employees; Federal employees, retirees, and surviving family of deceased federal employees (1998-1999) | Observational cohort | 3;3 | Overall, inertia in health plan enrollment decisions. For individuals affected by performance ratings, better scores were associated with increased likelihood of selecting the plan.
Scanlon, 2002^43^ | To assess effects of providing HEDIS and patient satisfaction ratings on plan choices | HEDIS; Health plan; General Motors; | General Motors employees (1996-1997); Private health plans (HMO only) | Observational cohort | 3;3 | Employees avoided plans with many below average ratings and would be willing to pay more to avoid plans with lower ratings, but were not strongly attacted to plans with many superior ratings.
Mennemeyer, 1997^52^ | To assess the relationship between the release of HCFA hospital-specific mortality rates and utilization (discharges); to compare the impact of releasing HCFA mortality rates to press reports of unexpected deaths, on utilizations. | HCFA; Hospital; U.S. | Community hospitals treating Medicare patients (1984-1992) | Observational cohort | 3;2 | Hospitals with mortality rates two times that expected by HCFA had less than one fewer discharge per week in the first year; press reports of single, unexpected deaths was associated with 9% reduction in hospital discharges within one year.
Vladeck, 1988^55^ | To examine relationship between mortality rate outlier status and hospital CABG volume/quality improvement activity following CSRS implementation | NYS CSRS; Hospital; New York | All New York general acute hospitals serving Medicare patients (∼1985 to ∼1986) | Analysis of Time Trend | 2;1 | No significant effect on occupancy rates
Mukamel, 1998^51^ | To measure the relationship between provider (hospital, physician) ratings in the CSRS and rates of growth in fee-for-service market share | NYS CSRS; Hospital; New York | All New York hospitals performing CABG (1990 to 1993) | Observational cohort | 2;1 | Hospitals with better outcomes experienced higher rates of growth in market share
Hannan, 1994^54^ | To determine if mortality rate outlier status was associated with overall improvement in risk-adjusted mortality and changes in provider volume of CABG operations performed following the implementation of the CSRS | NYS CSRS; Hospital; New York | All New York hospital performing CABG (1989 to 1992) | Observational cohort | 3;2 | No association between mortality rate outlier status and hospital volume
Chassin, 2002^36^ | To examine relationship between mortality rate outlier status and hospital CABG volume/quality improvement activity following the CSRS implementation | NYS CSRS; Hospital; New York | New York hospitals with the highest and lowest CABG mortality from 1989-1995 | Analysis of Time Trend | 2;1 | Small changes in market share and less than half the time in the expected direction
Jha, 2006^29^ | To examine the relationship between providers' CSRS rankings and market share; to examine impact of cardiac surgeons' performance on the likelihood of ceasing practice in New York | NYS CSRS; Hospital; New York | All New York hospitals performing CABG for more than 3 years (1989 to 2002) | Time Series (for market share analysis) | 3;2 | No significant relationship between ranking and subsequent market share
Baker, 2003^34^ | To examine market share following the release of risk-adjusted 30-day mortality rates for six acute conditions as part of the CHQC program | CHQC; Hospital; Northeast Ohio | 30 nonfederal hospitals (1991 to 1997) | Time Series | 3;2 | No statistically significant relationship overall between higher than expected mortality rates and market share
Romano, 2004^33^ | To examine the relationship between outlier status in California & New York public reports in three conditions/ procedures (CABG mortality in New York, AMI and postdiskectomy complications in California) and hospital volume | NYS CSRS and CA; New York and California | All licensed hospitals in New York State performing CABG , non-federal hospitals in California except Kaiser hospitals and state developmental and correctional hospitals | Time Series | 3;2 | No significant AMI-related volume changes among outlier hospitals. Slight increase in lumbar diskectomy-related volume for low-complication outliers. Significant transient increase in CABG volume for low-mortality hospitals and transient decrease in volume for high-mortality outliers.
Hibbard, 2005^4^ | To compare the impact of public (QualityCounts), internal (private) and no reporting on quality improvement activity, market share, and risk-adjusted performance (three clinical areas--hip/knee surgery, cardiac care, and obstetric care) | QualityCounts; Hospital; South central Wisconsin | Hospitals participating in Quality Counts; 24 Hospitals | Analysis of Time Trend | 2;2 | No significant changes in market share for hospital with publicly-reported data. No results given for internal or no reporting groups.
New articles not in Fung and colleagues
Cutler , 2004^32^ | To examine whether where patients go for bypass surgery (the distribution of patients across providers) affected by report cards | NYS CSRS; Hospital, New York State | All hospitals performing bypass surgery in New York (3,406 patients in the baseline year) | Observational, time series--across hospital rather than statewide trends. | 3;3 | Hospitals identified as high-mortality by the report experienced an approximated 10% decline in bypass surgery (4.9 fewer patients with hospital averages of 50 surgeries per month, significant at the 0.5 level); while low mortality hospitals do not experience an increase. The reduction is in low-severity, not high severity patients.
Harris, 2002^40^ | To determine if consumers perceive the quality of health plans and how quality relates to their choice of health plan. | N/A; Health plan; Minneapolis and St. Paul, MN | Randomly-selected eligible employees interviewed by phone. 721 interviewed. 91% response rate. Limited to unmarried employees with no dependents | Observational: cross sectional | 3;2 | Incorporating information from consumers about how important to them different attributes of health plans are improves models that explain health plan choice.
Dixon, 2008^27^ | To examine the influence of health plan (consumer driven health plan versus preferred provider organization) on the use of health-related information and health services | N/A; Health plan; Large manufacturing company | Health plan/HMO; US; Employees of a large manufacturing company | Observational, time series (no concurrent) | 2;1 | Enrollees in lower-deductible CDHP were most likely to start using information. Enrollees in high-deductible CDHP were more likely to use cost information than PPO enrollees. Variation in information seeking decreased throughout study.

Design ratings: 4 stars indicate a strong study design rating; while 1 star indicates a weaker study design rating.

Global ratings: 3 indicates great weight in the stratum's body of evidence; and 1 indicates little weight.