# EVIDENCE TABLES FOR KEY QUESTIONS #1 AND #2

Author, Year (ID) | Objective | Subject of public reporting; Hospital/ Health plan; Location | Sample | Design Type | Design Rating; Global Rating | Key Findings
Mazor, 2009^20^ | To evaluate consumers' responses to different approaches to public reporting of comparative hospital data on HAIs. | Healthcare-associated Infections (HAIs); Hospital; Worcester, MA | Random sample of residents; 201 completed surveys; Response rate 34% of those sent to valid addresses; 25% of all selected addresses. Age: Mean 51.7; 37.8% male; 28.4% HS education or less | Experiment (random sample; random assignment of versions of mock report) | 4;2 | The three report characteristics tested (consistency of hospital rating across indicators included; presenting results in words or charts, and including confidence intervals) had no significant impact on understandability. More respondents with a higher level of education (at least some college) rated 2 sections of the report as easier to understand verse those with high school education or less. For the other 5 sections the differences between education levels were not statistically significant. Age was not found to effect understandability.
Mazor, 2009^21^ | To understand consumer response to public reports and how reports might be improved. | HAIs; Hospital; Worcester, MA | Random sample of residents; 59 participants; 22 (37.3%) male; age range 24-82; mean 53.3; 25.4% high school education or less | In-depth interviews; random sample of residents invited to participant. | 2;2 | Most respondents had no prior knowledge/ understanding of HCI and this required explanation before different reports could be discussed. Inconsistent rankings across hospitals made it difficult for interviewees to pick the ‘best’ hospital. Format: number preferred over symbols; confidence intervals were confusing; interviewees unable to paraphrase definition of risk adjustment provided in the mock reports; print preferred to internet.
Richard, 2005^22^ | To use qualitative interviews to understand patients' views of report cards on cardiac care. | Cardiac report cards; Hospital; Canada | 7 cities with major cardiac programs; 91 cardiac patients | 63 individual interviews and 6 focus groups | 2;2 | Participants endorsed the idea of report cards, wanted to see improvement in report card scores over time, and would use them if relevant. Patients wanted report cards to contain additional information to supplement the traditional outcomes (e.g., mortality, morbidity), specifically the experiences of other cardiac patients and non-medical aspects of care. Dissemination ideas were varied and included important roles for family physicians and cardiologist to provide and explain the report cards.

Design ratings: 4 stars indicate a strong study design rating; while 1 star indicates a weaker study design rating.

Global ratings: 3 indicates great weight in the stratum's body of evidence; and 1 indicates little weight.