# SEARCH STRATEGIES

The database was Web of Science; the sub-databases were Science (SCI-EXPANDED), Social Science (SSCI), Arts & Humanities (A&HCI) and the Science & Social Sciences Proceedings (CPCI-S & CPCI-SSH).

40 Cited Author=(epstein a*) AND Cited Year=(2000)

Databases=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH Timespan=All Years

- PMID- 10770153
- TI - Public release of performance data: a progress report from the front.
- AU - Epstein AM
- PT - Comment
- PT - Editorial
- SO - JAMA. 2000 Apr 12;283(14):1884-6.

268 Cited Author=(epstein a*) AND Cited Year=(1998)

Databases=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH Timespan=All Years

- PMID- 9624015
- TI - Rolling down the runway: the challenges ahead for quality report cards.
- AU - Epstein AM
- SO - JAMA. 1998 Jun 3;279(21):1691-6.

197 Cited Author=(schneider e*) AND Cited Year=(1996)

Databases=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH Timespan=All Years

- PMID- 8657242
- TI - Influence of cardiac-surgery performance reports on referral practices and access to care. A survey of cardiovascular specialists.
- AU - Schneider EC
- AU - Epstein AM
- SO - N Engl J Med. 1996 Jul 25;335(4):251-6.

180 Cited Author=(schneider e*) AND Cited Year=(1998)

Databases=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH Timespan=All Years

- PMID- 9613914
- TI - Use of public performance reports: a survey of patients undergoing cardiac surgery.
- AU - Schneider EC
- AU - Epstein AM
- SO - JAMA. 1998 May 27;279(20):1638-42.

104 Cited Author=(fung c*) AND Cited Year=(2008)

Databases=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH Timespan=All Years

Fung CH, Lim YW, Mattke S, Damberg C, Shekelle PG. Systematic review: the evidence that publishing patient care performance data improves quality of care. Ann Intern Med. 148(2):111-23. [pmid: 18195336].

412 Cited Author=(marshall m*) AND Cited Year=(2000)

Databases=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH Timespan=All Years

Marshall MN, Shekelle PG, Brook RH, Leatherman S. Use of performance data to change physician behavior. JAMA. 2000;284(9):1079. [pmid: 10974682].

Marshall MN, Shekelle PG, Leatherman S, Brook RH. The public release of performance data: what do we expect to gain? A review of the evidence. JAMA. 2000;283(14):1866-74. [pmid: 10770149].

Marshall MN, Shekelle PG, Leatherman S, Brook RH. Public disclosure of performance data: learning from the US experience. Quality in Health Care. 2000;9(1):53-57. [pmid: 10848371].

2000. Dying to Know: Public Release of Information about Quality of Health Care. by. Marshall Martin, Shekelle Paul G, Brook Robert H, Leatherman Sheila. RAND MR-1255.