# SUMMARY AND DISCUSSION

This report summarizes a large body of evidence regarding: 1) teledermatology for the diagnosis of skin conditions, 2) teledermatology for the management of skin conditions, 3) clinical outcomes when teledermatology is used 4) the cost of teledermatology, and 5) key elements of and barriers to successful implementation of teledermatology. Differences in study settings, skin conditions, trial methodology, and outcomes weaken the strength of the evidence. When appropriate, we calculated weighted pooled estimates for similar studies. Summarized evidence indicates that diagnostic accuracy of usual care (in-person dermatology visit) is 5 to 19% (average absolute difference) better than teledermatology. When dermatoscopy-trained teledermatologists are available, teledermatoscopy improves diagnostic accuracy of circumscribed skin lesions, although generally not to a level exceeding usual care. We found that diagnostic and management concordance of usual care (in-person dermatology visit) and teledermatology is good for SAF and may be better for LI, likely due to the ability to obtain additional history in the LI setting. Limited data from two SAF studies, both from the same VA medical center, show that while overall management accuracy rates are equivalent for SF teledermatology and usual care, teledermatology is significantly less accurate for malignant skin lesions including squamous cell carcinoma, basal cell carcinoma, and melanoma. While this finding needs to be confirmed in other settings and in other study populations, awareness of this potential limitation of teledermatology in a VA population is important.

Our search found very little evidence on clinical course, an important limitation also noted in a 2006 report from the Agency for Healthcare Research and Quality (AHRQ).95 Studies evaluating visits avoided uniformly showed that teledermatology can decrease the number of dermatology clinic visits. While studies of patient satisfaction were generally positive, factors such as distance to the dermatology clinic and wait times for an in-person appointment play important roles in patient satisfaction. Cost analyses were limited by broad variations in cost assessment parameters and perspectives. The majority of studies found teledermatology to be cost effective if certain critical assumptions were met; the most important included patient travel distance, teledermatology volume, and costs of usual care.

While evaluation of accuracy and reliability of a new technology is important, many more factors become important in evaluating clinical outcomes. Especially for SAF teledermatology, if recommendations are not communicated to the patient or not implemented by the referring provider, patient outcome is likely to be poor, despite a highly accurate and reliable technology. Because teledermatology involves a shift in workload, ongoing support (i.e., funding for a teledermatology technician, training for primary care physicians, additional dermatology staff) is critical. Barriers to implementation and key factors for success are highly dependent on the intended setting. Identifying site-specific barriers is critical to successful implementation.

## CONCLUSIONS

In general, diagnostic accuracy of usual care (in-person dermatology care) is better than SAF teledermatology. Both SAF as well as LI teledermatology appear to have acceptable diagnostic and concordance compared to clinic dermatology. SAF is currently more widely used in the VA. Little information exists on the impact of teledermatology on clinical outcomes and management compared to management provided by in clinic dermatologists. This may be particularly important for dermatologic conditions with potentially serious outcomes (e.g., malignant and premalignant lesions). Patient satisfaction with teledermatology is relatively high though there are individuals who have strong beliefs for a particular approach and little information exists from non-research settings regarding patient satisfaction. Cost analysis studies are limited in number and relevance to current VA practice. Identifying and removing barriers to successful implementation is essential. Studies are needed to compare teledermatology with primary care to inform decision making about the best way to provide dermatology in areas without reliable access to in-person dermatology (e.g., rural areas). Given the results of this review, the potential benefits of teledermatology (e.g., decreased patient travel, shorter time to intervention, primary care provider education) need to be evaluated in the context of its limitations including inferior diagnostic accuracy and management accuracy, especially for malignant skin neoplasms.

## FUTURE RESEARCH RECOMMENDATIONS

Additional research is needed to determine the long-term effectiveness, feasibility, satisfaction, and cost-effectiveness of teledermatology (especially store and forward methodologies) integrated into primary care settings with outcomes related to the impact of teledermatology on patient management and clinical outcomes. Standardized reporting of diagnostic, management, and outcome accuracy and concordance are needed. Future studies should attempt to distinguish between lack of concordance between two in-person dermatologists and lack of concordance between teledermatology and in-person dermatology. Studies that blind assessors to the patient/ lesion are preferred to reduce bias in outcome assessment. Additional outcomes could assess the impact on primary care practice, referring provider satisfaction, and follow-up patterns. Barriers to successful implementation need to be identified that incorporate differences in patient populations, lesion severity, and acuteness; distance traveled and availability of local dermatologists; and other clinical setting issues in order to determine the relative feasibility and effectiveness of different teledermatology strategies in different settings (e.g., Intrasite, Intersite, New Site).

Importantly, while this review suggests that diagnostic accuracy of teledermatology is inferior to in-person dermatologic care, teledermatology may still be superior to dermatologic care provided by a non-dermatologist; studies are needed to compare teledermatology with primary care. Additional research is needed to determine the long-term outcomes and cost-effectiveness of teledermatology (especially store and forward methodology) in the VA setting. We are aware of one randomized controlled study in progress (Impact of Teledermatology on Health Services Outcomes in the VA HSRD IIR05-278, PI John Whited) which will assess quality of life and nine-month clinical course outcomes in two VA SAF teledermatology programs.

We recommend prioritizing studies which address the following outcomes:

1. Comparison of teledermatology with dermatologic care by a VA primary care provider or a dermatology trained nurse practitioner: This study setting is very relevant to remote/ inaccessible locations where no in-person dermatologist is available (e.g., Hawaii, Alaska, remote rural clinics). Relevant outcomes include diagnostic accuracy and concordance, management accuracy and concordance, long-term outcomes, cost-effectiveness, and patient/ provider satisfaction.
2. Comparison of teledermatology with in-person care by a dermatologist in a VA setting: Long-term clinical outcomes, patient and provider satisfaction, and cost analyses are needed. Additional outcomes should assess the impact of teledermatology on primary care practice and follow-up patterns. Barriers to successful implementation need to be identified that incorporate differences in patient populations, skin condition severity and acuteness, distance traveled, and availability of on-site dermatologists.
3. Comparison of specific imaging techniques to enhance teledermatology accuracy: More research is needed to understand the limitations of teledermatology (e.g., malignant skin neoplasms) and whether specific techniques (e.g., polarized light dermatoscopy, contact immersion dermatoscopy, and confocal microscopy) can overcome these limitations.
4. Evaluation of teledermatology to provide follow-up dermatologic care: Clinical outcomes, feasibility, and cost analyses are needed to evaluate chronic skin conditions which require frequent monitoring such as leg ulcers, post-operative wound care, and chronic dermatitis.