# RESULTS

## LITERATURE FLOW

The OVID MEDLINE search yielded 559 references with 3 duplicates for a total of 556 unique references. The PubMed search yielded 587 references. When the results from these searches were combined, 486 duplicate references were eliminated resulting in 657 titles and abstracts for review. From the 657 titles and abstracts, 473 references were excluded. The full text of 184 references was then reviewed and another 100 references were excluded. One additional reference (a recent publication) was added resulting in a total of 85 studies included in the report. Figure 1 details the exclusion criteria and the number of references related to each of the key questions.

Figure 1 Reference Flow Chart

*Search results from OVID MEDLINE (556) and PubMed (587) were combined, removing duplicate entries (486)

**Manuscript reference list includes additional references cited for background and methods plus Web sites relevant to KQ5

***Total ≠ 85; many studies addressed more than one key question

## KEY QUESTION 1. 1a. How does the accuracy of teledermatology compare to usual care (in-person dermatology) for the diagnosis of skin conditions? 1b. How does the concordance of teledermatology compare to usual care (in-person dermatology) for the diagnosis of skin conditions?

Summary of Studies for Key Questions 1 and 2 (Table 2 and Appendix E)

The study design, population and study characteristics, teledermatology characteristics, outcomes evaluated, and the quality rating for each of the included studies are presented in Appendix E.

Table 2 Summary of Study Characteristics for Teledermatology Studies (KQ1 and KQ2)

| Store and Forward (N=41) | | Live Interactive (N=10)
Characteristic | Mean and/or Range | Number of Studies Reporting | Mean and/or Range | Number of Studies Reporting
Number of Subjects: Repeated measure studies | 12 to 882 (NR in 3) | 40 | 51 to 351 | 10
Randomized controlled trials (TD arm only) | 92 | 1 | NA | 0
Studies involving US Military Personnel or Veterans: Number of subjects | 129 to 728 | 5 | 102 | 1
Age of Subjects in Years: All studies, weighted mean (mean range) | 53 (28 to 71) | 19 | 40 (35 to 47) | 6
Studies with children/adolescents (<18 years of age) in addition to adults | NR | 13 | NR | 7
Gender: Female: mean % (mean range) | 43 (2 to 71) | 21 | 54 (5 to 84) | 9
Race: Caucasian: mean % (mean range) | 93 (80 to 99) | 5 | 72 (60 to 85) | 3
Black: mean % (mean range) | 5 (12 to 20) | 5 | 27 (12 to 40) | 3
Other: mean % (mean range) | 2 (<1 to 5) | 5 | 1 (0 to 3) | 3
Study Location in U.S: Number of subjects per study | 12 to 728 | 12 | 51 to 131 | 5
Skin Condition Characteristics: Rashes and lesions number of subjects per study | 23 to 404 | 14 | 60 to 351 | 9
Lesions only number of subjects per study | 12 to 882 (NR in 2) | 22 | 51 | 1
Pigmented lesions only number of subjects per study | 12 to 611 (NR in 1) | 12 | NA | 0
Non-pigmented lesions only number of subjects per study | 728 (NR in 1) | 2 | NA | 0
Outcomes Assessed: Diagnostic accuracy number of subjects per study | 12 to 728 | 19 | 102 | 1
Diagnostic concordance number of subjects per study | 12 to 882 | 27 | 51 to 351 | 10
Management accuracy number of subjects per study | 542 to 728 | 2 | NA | 0
Management concordance number of subjects per study | 12 to 882 | 14 | 51 to 351 | 4

### Description of store and forward studies

#### Study design and location

Forty-one unique store and forward studies (reported in 42 publications) enrolling between 12 and 882 subjects met inclusion criteria for Key Questions 1 and 2.^5,6,7,8,9,10,11,12,13,14^.15,16,17,18,19,20,21,22,23,24,25,26,27,28,29.^30,31,32,33,34,35^.36,37,38,39,40,41,42,43,44,45.^46^ The majority of these studies each evaluated fewer than 200 subjects. All studies utilized a repeated measure study design with the exception of one randomized, controlled trial (RCT).12 Based on location, most of the studies were conducted in the United States (n = 12),5,6,7,23,25,26,34,36,38,42,43,44,46 followed by the United Kingdom (n = 9),12,13.^16,19,30,31,33,39,45^ Italy, (n = 6),8,9,21,22,37,40 Spain (n = 4),10,11,14,18 Australia/New Zealand (n = 3),15,32,41 Turkey (n = 2),17,20 and one study each from Germany,24 Netherlands,25 Pakistan,28 Brazil,29 and Switzerland.35

#### Patient and skin condition characteristics

Five studies (six publications) involved U.S. military personnel and/or veterans.5,6,26,27,42,43 The study by Pak also included beneficiaries of U.S. military personnel.26,27 Fewer than half (19/41, 46.3%) of the studies reported mean age; of those reporting, mean age was 53 years (range of means 28 to 71 years). Thirteen studies included subjects less than 18 years of age, in addition to adults.7,9,14,15,17,18,21,22,30,31,36,37,40 In 21 studies reporting gender, most of the subjects were male (57% overall, range 29% to 98%). Only 5 studies, all conducted in the United States, reported racial or ethnic characteristics.5,6,7,26,27,42 The majority of subjects in those 5 studies were Caucasian (93%).

Fourteen studies included patients with a variety of skin conditions including rashes (e.g., papulosquamous, eczematous) as well as circumscribed lesions (isolated skin growths).7,12,17,20,25,26,27, 28,32,33,36,38,42,45,46 Twenty-two studies evaluated only patients with circumscribed lesions (suspected skin cancer and/or isolated skin growths); of these, twelve studies exclusively evaluated subjects with pigmented skin lesions5,9,14,18,21,22,24,30,31,35,37,40 and two studies enrolled only subjects with non-pigmented skin lesions.6,8 The remaining eight studies only included subjects with circumscribed lesions but did not specify pigmentation status.10,11,13,15,16,23,34,43 Five studies did not provide details on types of skin conditions included.19,29,39,41,44

### Description of live interactive studies

#### Study design and location

Ten unique live interactive, repeated measure studies enrolling between 51 and 351 subjects met inclusion criteria for Key Questions 1 and/or 2.^7,17,47,48,49,50,51,52,43,54^ Two of the studies also had a store and forward component.7,17 One-half of the studies were conducted in the U.S. (n = 5).7,49,51,52,54 Two studies were performed in the United Kingdom,48,50 and one study each was completed in Turkey,17 Norway,47 and New Zealand.53

#### Patient and skin condition characteristics

One live interactive study involved U.S. veterans.51 For the six studies reporting average age,7,17,47,50,52,54 the mean age (40 years; mean range 35 to 47 years) was younger and less varied compared to the store and forward studies. Seven studies included children or adolescent subjects in addition to adults.7,17,47,48,50,53,54 Three U.S. studies reported racial or ethnic characteristics,7,51,54 overall, the majority of subjects in these three studies were Caucasian (72%), although the study by Lowitt included a significant number of African-American participants (40%).51 Nearly all studies reported gender (n=9), with women comprising the majority of subjects (54%; mean range 5 to 84%).

Nine studies included patients with a variety of skin conditions including rashes (e.g., papulosquamous, eczematous) as well as circumscribed lesions (isolated skin growths).7,17,47,48,49,50,51,53,54 One study evaluated only patients with circumscribed lesions (suspected skin cancer and/ or isolated skin growths).52 No live interactive studies focused specifically on either pigmented or non-pigmented lesions.

### Quality assessment

Most included studies assessing accuracy and concordance (Key Questions 1 and 2) utilized methods to reduce sources of bias, particularly related to appropriate use of index and reference tests. However, the majority of studies using store and forward technology did not clearly address patient selection biases such as enrolling a representative spectrum of general dermatological patients or clearly describing exclusion criteria. Both store and forward and live interactive studies generally did not account for all patients at the end of the study or include patients with uninterpretable results (Figures 2 and 3). Among individual studies, 11 of 41 SAF and 3 of 10 LI publications adequately reported on least 10 of 14 quality assessment items; most lower quality studies failed to adequately describe or enroll a representative spectrum of patients or account for all originally enrolled patients in data analysis.

Figure 2 Quality of Store and Forward Studies (N=41)

Figure 3 Quality of Live Interactive Studies (N=8)

Quality of the 2SAF and U Studies is included in Figure 2.

#### QUESTION 1a: Diagnostic Accuracy

(See Table 3, Figures 4a and 4b)

##### Overall Comparisons

Twenty studies (19 SAF, 1 LI) reported diagnostic accuracy defined as matching of teledermatology diagnosis with histopathology diagnosis or other lab test. Results were reported as percent match between the primary diagnosis and/or aggregated diagnoses (primary plus differential) and histopathology, kappa statistic, and/or sensitivity and specificity. Fifteen studies also reported diagnostic accuracy of usual care (in-person dermatology diagnoses), allowing for direct comparisons of accuracy rates between these two methods of care. Ten of these 15 studies found that diagnostic accuracy for usual care (in-person dermatology visit) was better than teledermatology,5,6,8,15,24,34,37,38,40,42 3 studies reported better diagnostic accuracy for teledermatology,30,35,51 and 2 reported mixed results.26,27,43 The three studies which reported higher diagnostic accuracy rates for teledermatology were comprised of smaller sample sizes (n=11,^51^ n=51,^35^ n= 138^30^). In the small pilot study by Lowitt51 the difference between accuracy rates was the result of one lesion, a difference likely due to chance. In the study by Braun35 involving 55 pigmented skin lesions in 51 patients, diagnoses were compared between six general dermatologists in private practice (usual care) with a dermatoscopic expert at a university pigmented skin lesion clinic (teledermatologist). The better diagnostic accuracy of the teledermatologist in this study was likely due to dermatoscopic expertise; the six general dermatologists had “different levels of experience” whereas the teledermatologist was a dermatoscopic expert. In the larger study by Jolliffe31 involving 144 pigmented skin lesions in 138 patients, the same dermatologist who saw the patient in clinic (and likely followed up on biopsy results) served as teledermatologist (several months later), possibly resulting in recall bias.

Table 3 Studies Reporting Diagnostic Accuracy using Histopathology/Lab Tests as Gold Standard (KQ1a) (See Appendix D for abbreviations)

Study | Diagnostic Accuracy - Teledermatology % Correct, Kappa, or Sensitivity/Specificity | Diagnostic Accuracy - Usual Care % Correct, Kappa, or Sensitivity/Specificity | Mean Absolute Difference, % Correct
A. Store and forward pigmented skin lesion studies (n=10)
Warshaw 2009^5^ VA 542 Pts 542 PSL | Aggregated: 52% (282/542) 65% (352/542) PLD 67% (363/542) CID Primary: 50% (271/542) 47% (255/542) PLD 57% (309/542) CID | Aggregated: 80% (434/542) Primary: 59% (320/542) | −28% −9%
Moreno-Ramirez 2006^14^ 61 Pts No. PSL NR | k=0.91 (95% CI 0.82, 1.00) k=0.94 TDSC (95% CI 0.88, 1.00) | NR | NA
Moreno-Ramirez 2005^18^ No. Pts NR 57 PSL | k=0.79 (95% CI 0.70, 0.89) | NR | NA
Ferrara 2004^21^ 12 Pts 12 PSL | Primary: 83% (10/12) TDSC | NR | NA
Piccolo 2004^22^ 73 Pts 77 PSL | Mean Sensitivity for 11 TDs: 0.91 (SD 0.09) (Range 0.83–1.00) Mean Specificity for 11 TDs: 0.95 (SD 0.04) (Range 0.92–1.00) | NR | NA
Coras 2003^24^ No. Pts NR 45 PSL | Primary: 89% (40/45) TDSC For Malignant vs. Benign: Sensitivity: 0.86 Specificity: 0.92 | Primary: 91% (41/45) DSC For Malignant vs. Benign: Sensitivity: 0.86 Specificity 0.96 | −2%
Jolliffe 2001^30^ 138 Pts 144 PSL | Primary: 47% (68/144) (95% CI 39%, 55%) TD also served as CD | Primary: 43% (63/144) (95% CI 35%, 51%) TD also served as CD | 4%
Braun 2000^35^ 51 Pts 55 PSL | Primary: 75% (41/55) TDSC | Primary: 64% (35/55) DSC | 11%
Piccolo 2000^37^ 40 Pts 43 PSL | Primary: 87% avg for 6 derms TDSC (range 81%–95%) | Primary: 91% (39/43) DSC | −4%
Piccolo 1999^40^ 66 Pts 66 PSL | Primary 86% (57/66) TDSC | Primary 92% (61/66) DSC | −6%
B. Store and forward skin lesion studies (n=6)
Warshaw 2009^6^ VA 728 Pts 728 SL | Aggregated: 56% (408/728) 65% (473/728) PLD Primary: 43% (313/728) 47% (342/728) PLD | Aggregated: 76% (553/728) Primary: 56% (408/728) | −20% −13%
Fabbrocini 2007^8^ No. Pts NR 44 SL | k=0.44 k=0.45 CID | k=0.52 k=0.70 CID | NA
Ferrandiz 2007^10^ 134 Pts No. SL NR (73% NMSC) | Primary: 85% (110/130) k=0.86 (95% CI 0.83, 0.89) | NR | NA
Oakley 2006^15^ No. of Pts NR 29 SL | Primary: 71% (34/48) (95% CI 56, 83) 38 TDs including 6 residents | Primary: 72% (21/29) (95% CI 53, 87%) 5 CDs including 2 plastic surgeons | −1%
Barnard 2000^34^ 25 “cases” | Aggregated: 73% avg for 8TDs (range 54%–80%) | Aggregated: 84% | −11%
Whited 1998^43^ VA 9 SL | Aggregated average: 84% Aggregated (2 TDs): 89% (8/9) 78% (7/9) Primary average: 59% Primary (2 TDs): 78% (7/9) 22% (2/9) | Aggregated: 78% (7/9) Primary: 67% (6/7) | 6% −8%
C. Store and forward general studies (n=3)
Pak 2003 (part II)26 DoD 119 Pts 119 Conditions | Aggregated: 78% (No. NR) Primary 19% | Aggregated: 60% Primary: 73% | 18% −54%
Krupinski 1999^38^ 104 Pts 104 Conditions | Primary: 76% Avg for 3 TDs | Primary/Aggregated: 89% Avg for 3 CDs (Combo 58% Primary; 42% Aggregated) | −13%
Whited 1999^42^ VA No. Pts NR 79 Conditions | Aggregated average: 77% Aggregated (3 TDs): 68% (95% CI 58%, 78%) 78% (95% CI 69%, 87%) 85% (95% CI 77%, 93%) Primary average: 59% Primary (3 TDs): 53% (95% CI 42%, 64%) 63% (95% CI 52%, 74%) 62% (95% CI 51%, 73%) | Aggregated: 85% (95% CI 77%, 93%) Primary: 59% (95% CI 48%, 70%) | −8% 0
Weighted mean difference for aggregated diagnosis studies (range of mean differences; # studies) | | −19% (−28 to 18%; 6 studies)5,6,26,34,42,43
Weighted mean difference for primary diagnosis studies (range of mean differences; # studies) | | −11% (−54 to 11%; 11 studies)5,6,15,24,26,30,35,37,40,42,43
Weighted mean difference for primary diagnosis pigmented skin lesion studies (range of mean differences; # studies) | | −5% (−9 to 11%; 6 studies)5,24,30,35,37,40
D. Live interactive studies (n=1)
Lowitt 1998^51^ VA No. Pts NR 11 Conditions | Aggregated: 73% (8/11) | Aggregated: 64% (7/11) | 9%

Figure 4a Aggregated Diagnostic Accuracy of Store and Forward Studies

Figure 4b Primary Diagnostic Accuracy of Store and Forward Studies

##### Pooled Comparisons

Statistical pooling of the six SAF studies reporting aggregated diagnostic accuracy rates found that the weighted mean absolute difference was 19% better for usual care than teledermatology.5,6,26,27,34,42,43 For the 11 SAF studies5,6,15,24,26,27,30,35,37,40,42,43 which reported primary diagnostic accuracy rates, the weighted mean absolute difference was 11% better for usual care than teledermatology. Similarly, the weighted mean absolute difference for primary diagnostic accuracy for six pigmented skin lesion studies was also better (5%) for usual care than teledermatology.5,24,30,35.^37,40^ A recent unpublished analysis of teledermatology data from 1514 biopsied skin neoplasms found that teledermatology was significantly less accurate for eleven common skin neoplasms including melanoma, squamous cell carcinoma, and basal cell carcinoma.55

##### Value of Teledermatoscopy

Four studies evaluated teledermatology with standard macro images and teledermatoscopy.5,6,8,14 In general, teledermatology accuracy rates improved up to 15% (absolute difference) with teledermatoscopy. A recent unpublished analysis found that diagnostic accuracy significantly improved with polarized light teledermatoscopy specifically for squamous cell carcinoma and basal cell carcinoma.55

##### Conclusion

The evidence shows that diagnostic accuracy of usual care (in-person dermatology) is better than teledermatology (aggregated diagnostic accuracy absolute difference 19%; primary diagnostic accuracy absolute difference 5% and 11%). When dermatoscopy-trained teledermatologists are available, teledermatoscopy may be beneficial for isolated skin lesions.

#### QUESTION 1b: Diagnostic Concordance

(See Table 4, Figures 5a, 5b, 6a and 6b)

##### Overall Comparisons

Thirty-seven (27 SAF; 9 LI; 1 SAF+LI) studies reported diagnostic concordance (simple agreement without verification by histopathology or laboratory test) between usual care (in-person dermatology) and teledermatology. Thirty-five studies (25 SAF, 9 LI, 1 SF+LI) reported concordance as percent agreement for exact diagnosis (primary-see figures 5b and 6b, aggregated-see figures 5a and 6a, and/or not specified,7,45,46 malignant/ benign status,13,29,39 or diagnostic category.51 Seven studies in six publications reported kappa statistics7,11,18,29,52,53 and three studies reported sensitivity and specificity.13,29,39

Table 4 Studies for Reporting Diagnostic Concordance between Teledermatology and Usual Care (In-Person Dermatology) (KQ1b)^*^

Study No. of subjects No. of skin conditions | Percent concordant | Kappa statistic | Sensitivity and Specificity
A. Store and forward pigmented skin lesion studies (n=2)
Moreno-Ramirez 2005^18^ 108 Pts No. PSL NR | NR | k=0.93 (95% CI 0.87, 0.98) TD = CD | NR
Piccolo 1999^40^ 66 Pts 66 PSL | Primary: 91% (60/66) DSC | NR | NR
B. Store and forward skin lesion studies (n=6)
Moreno-Ramirez 2007^11^ 882 Pts 882 SL | NR | k=0.81 (95% CI 0.78, 0.84) | NR
Bowns 2006^13^ 256 Pts 256 SL | Primary: 69% (159/230) agreement on specific diagnosis TDSC: 75% (193/256) agreement on benign or malignant | NR | TD: Sensitivity=0.98 (95% CI 0.92, 0.99) Specificity= 0.39 (95% CI 0.32, 0.47) TDSC: Sensitivity=0.98 (95% CI 0.92, 0.99) Specificity=0.43 (95% CI 0.36, 0.51)
Oakley 2006^15^ 73 Pts 109 SL | Aggregated: 64%, No. NR Primary: 53% (100/189) (95% CI 46, 60%) TD=38 dermatologists including residents CD=3 dermatologists and 2 plastic surgeons | NR | NR
Mahendran 2005^16^ 163 Pts 163 SL | Aggregated: 65% (106/163) Primary: 48% (78/163) | NR | NR
Barnard 2000^34^ 50 “cases” | Aggregated: 90%, No. NR (range for 8TDs 86–96%) Primary: 77%, No. NR (range for 8 TDs 67%–84%) | NR | NR
Whited 1998^43^ VA 12 Pts 10 SL | 2TDs - Aggregated: 90% (9/10) 100% (10/10) Primary: 80% (8/10) 60% (6/10) | NR | NR
C. Store and forward general studies (n=19)
Edison 2008^7^ 110 Pts 110 Conditions | Primary: 73% (80/110) (95% CI 64, 81%) | k=0.71 (95% CI 0.67, 0.76) | NR
Bowns 2006^12^ 92 Pts 92 Conditions | Primary: 55% (51/92) | NR | NR
Baba 2005^17^ 228 Pts 242 Conditions | Primary: TD also served as CD: 81% (197/242) TD not the same as CD: 75% (181/242) | NR | NR
Tucker 2005^19^ 75 Pts 84 Conditions | Aggregated: 68% (57/184) Primary: 56% (47/84) | NR | NR
Oztas 2004^20^ 125 Pts 125 Conditions | Primary: 70% (88/125) Average of 3 TDs | NR | NR
Du Moulin 2003^25^ 106 Pts 106 Conditions | Aggregated: 63% (67/106) Primary: 54% (57/106) | NR | NR
Pak 2003^27^ DoD 404 Pts 404 Conditions | Aggregated: 91% (366/404) Primary: 70% (283/404) TD also served as CD (included residents) | NR | NR
Rashid 2003^28^ 33 Pts 33 Conditions | Aggregated: 81% (27/33) | NR | NR
Oliveira 2002^29^ 92 Pts No. Conditions NR | 98% (88/90) for benign vs. malignant | k=0.87 | Sensitivity=1.00 Specificity=0.98
Lim 2001^32^ 23 Pts 27 Conditions | Aggregated: 96%, No. NR Primary: 88%, No. NR TD also served as CD | NR | NR
Taylor 2001^33^ 188 Pts No. of Conditions NR | Aggregated: 60%, No. NR Primary: 50%, No. NR | NR | NR
High 2000^36^ 92 Pts 106 Conditions | Aggregated: 85% (84/99) 64% (49/77) 77% (76/99) Primary: 70% (69/99) 64% (49/77) 77% (76/99) | NR | NR
Krupinski 1999^38^ 308 Pts 308 Conditions | 3 TDs (some also served as CD) Primary: 81%, No. NR 84% 85% Average of all 3: 83% | NR | NR
Lewis 1999^39^ 56 Cases | 93% No. NR (likelihood of benign vs. malignant on 1–5 scale) | NR | Sensitivity=0.88 Specificity=0.80 (benign vs. malignant)
Tait 1999^41^ 30 Pts No. of Conditions NR | Aggregated: 100% (30/30) Primary: 83% (25/30) TD also served as CD | NR | NR
Whited 1999^42^ VA 129 Pts 168 Conditions | 3 TDs - Aggregated: 84% (95% CI 79%, 90%) 83% (95% CI 78%, 89%) 95% (95% CI 92%, 98%) Primary: 41% (95% CI 34%, 49%) 44% (95% CI 36%, 52%) 52% (95% CI 45%, 60%) Average = 46% | NR | NR
Kvedar 1997^44^ No. of Pts NR 123 Conditions | 2 TDs - Aggregated: 70% 67% Primary: 61% 64% | NR | NR
Lyon 1997^45^ 100 Pts 100 Conditions | 93% (93/100) TD staff; CD resident | NR | NR
Zelickson 1997^46^ 29 Pts 30 Conditions | 88% (53/60) Combination of 2–3 TDs | NR | NR
D. Live interactive studies skin lesion studies (n=1)
Phillips 1998^52^ 51 Pts 107 SL | Primary: 59% (63/107) | k=0.32 | NR
E. Live interactive general studies (n=8)
Edison 2008^7^ 110 Pts 110 Conditions | 80% (88/110) (95% CI 73%, 88%) | k=0.79 95% CI 0.75, 0.83) | NR
Nordal 2001^47^ 112 Pts 112 Conditions | Aggregated: 86% (97/112) Primary: 72% (81/112) | NR | NR
Gilmour 1998^48^ 126 Pts 155 Conditions | Aggregated: 78% (121/155) Primary: 57% (88/155) TD also served as CD in 51% (79/155) of cases | NR | NR
Lesher 1998^49^ 60 Pts 68 Conditions | Aggregated: 99% (67/68) Primary: 78% (53/68) | NR | NR
Loane 1998^50^ 351 Pts 427 Conditions | Aggregated: 82% (352/427) Primary: 67% (285/427) TD also served as CD in 63% (226/427) of cases | NR | NR
Lowitt 1998^51^ VA 102 Pts 130 Conditions | Aggregated: 80% (104/130) Agreement for diagnostic category | NR | NR
Oakley 1997^53^ 104 Pts 135 Conditions | Aggregated: 82% (110/135) Primary: 75% (101/135) TD also served as CD in 79% of cases | k=0.62 (TD not the same as CD) k=0.91 (TD also served as CD) | NR
Phillips 1997^54^ 60 Pts 79 Conditions | Primary: 77% (61/79) | NR | NR
F. Live interactive and store and forward studies (n=1)
Baba 2005^17^ 228 Pts 242 Conditions | Primary: 90% (218/242) TD also served as CD 82% (199/242) TD not the same as CD | NR | NR

* Results for staff dermatologists unless otherwise reported.

Figure 5a Aggregated Diagnostic Concordance of Store and Forward Studies

Figure 5b Primary Diagnostic Concordance of Store and Forward Studies

Figure 6a Aggregated Diagnostic Concordance of Live Interactive Studies

Figure 6b Aggregated Diagnostic Accuracy of Store and Forward Studies

##### Primary Diagnostic Concordance of Live Interactive Studies

Aggregated diagnostic agreement was assessed in 4 studies (Table 4, Figure 5a). Two medium-sized studies, both of which evaluated circumscribed skin lesions, found similar aggregated diagnostic concordance rates of 64% (n=109^15^) and 65% (n=163^16^). Two smaller lesion studies found higher aggregated diagnostic concordance rates, 90% (n=50^34^) and 95% (n=10^43^). Weighted average aggregated diagnostic concordance of these four lesion studies was 64.4% (230/358). Primary diagnostic concordance (Table 4, Figure 5b) was assessed in one pigmented lesion study40 and five skin lesion studies;13,15,16,34,43 concordance ranged from 48% to 91%. Weighted average for these six studies was 62.3% (443/708).

##### Percent Concordance - SAF General Study Results

Nineteen studies involving a range of dermatologic conditions (lesions and rashes) evaluated diagnostic concordance (Table 4, Figures 5a and 5b). Aggregated diagnostic agreement was assessed in ten of these studies and ranged from 60–100%. The three highest rates were from studies in which the same dermatologist served as both clinic dermatologist and teledermatologist and did not appear to be blinded to index results (91%,26,27 96%,32 and 100%^41^). Excluding those three studies, the weighted average aggregated diagnostic agreement rate was 65.3% (703/1077). Primary diagnostic agreement was assessed in 14 studies and ranged from 46% to 88%. Excluding the three studies where the same dermatologist served as both clinic dermatologist and teledermatologist (70%,26,27 88%,32 and 83%^41^), the weighted average primary diagnostic concordance rate was 66.3% (1227/1851).

##### Percent Concordance - LI Studies

Six LI studies reported aggregated diagnostic concordance rates ranging from 78 to 99% (Figure 6a); excluding three studies in which the same dermatologist served as both clinic dermatologist and teledermatologist for >50% of cases (78%,48 82%,53 82%^50^), the weighted average aggregated diagnostic concordance was 86.5% (268/310). Eight LI studies reported primary diagnostic concordance rates ranging from 57–78% (Figure 6b); excluding three studies in which the same dermatologist served as both clinic dermatologist and teledermatologist (67%,48 75%,53 67%^50^), the weighted average primary diagnostic concordance rate was 70.5% (258/366).

##### Kappa, Sensitivity, Specificity

SAF Studies: Kappa values ranged from 0.71 to 0.93 for the four SAF teledermatology studies reporting this statistic.7,11,18,29 Excluding the one study with likely bias (same dermatologist served as both clinic dermatologist and teledermatologist, k=0.93^18^), kappa values varied by 16 points and values indicated substantial agreement (k=0.71,^7^ k=0.81,^11^ k=0.87^29^). Sensitivity and specificity was reported in three studies (utilizing the clinic dermatologist’s assessment as the gold standard); all three evaluated only agreement for benign or malignant status, not specific diagnosis. Sensitivity ranged from 0.88 to 1.0 and specificity ranged from 0.39 to 0.98.

LI Studies: Three LI studies reported kappa values of 0.32,^52^ 0.62,^53^ and 0.79.^7^ The study by Phillips52 had the lowest kappa value (k=0.32); this study employed a live interactive system which may not have been able to provide the detail required for the individual skin lesions evaluated. No LI studies evaluated sensitivity or specificity.

##### LI+SAF Study Results

Only one study evaluated a combination of SAF and LI teledermatology.17 In that study, primary diagnostic accuracy concordance was 82%, higher than the weighted average concordance rate of SAF studies (66.3%) and LI studies (70.5%).

##### Conclusion

Based on the data above, the weighted mean aggregated diagnostic concordance rates for SAF teledermatology were similar for lesion studies (64%) and general studies (65%); the rate for LI (87%) was higher, but this was based on significantly fewer patients (approximately 300 vs. >1,000). The weighted mean primary diagnostic concordance for SAF teledermatology was also similar for lesion studies (62%) and general studies (66%); the rate for LI studies was higher (71%) but based on fewer patients. In summary, diagnostic concordance of SAF is good and may be better for LI, possibly due to the ability to obtain additional history in the LI setting.

## KEY QUESTION 2. 2a. How does the accuracy of teledermatology compare to usual care (in-person dermatology) for clinical management of skin conditions? 2b. How does the concordance of teledermatology compare to usual care (in-person dermatology) for clinical management of skin conditions?

### QUESTION 2a. How does the accuracy of teledermatology compare to usual care (in-person dermatology) for clinical management of skin conditions?

(See Table 5)

Only two studies assessed management accuracy (expert panel consensus of management based on histopathologic diagnosis) of usual care and teledermatology.5,6 Both were large, utilized SAF teledermatology, were completed at the same VA, enrolled primarily older, Caucasian, men, and involved circumscribed skin lesions. In both studies, overall management was equivalent (defined as a ±10% difference) for usual care and teledermatology (macro images as well as two types of dermatoscopic images). Although the overall management accuracy rates were not significantly different, further unpublished analysis of this data provided by the lead author of this evidence report found that nine melanomas were mismanaged with teledermatology as compared to two with usual care, and management accuracy of usual care was superior to teledermatology (macro images or dermatoscopic images) not only for melanoma but also for basal cell carcinoma, squamous cell carcinoma, and premalignant actinic keratoses.55

Table 5 Studies Reporting Management Accuracy using Histopathology/Lab Tests as the Gold Standard (KQ2a)

Study | TD Management Accuracy, % Correct | CD Management Accuracy, % Correct | Absolute Mean Difference, % Correct
A. Store and forward studies
Warshaw 2009^6^ VA 728 Pts 728 SL | 79% (574/728) 80% (581/728) PLD | 84% (608/728) 84% (609/728) PLD | −5% −4%
Warshaw 2009^5^ VA 542 Pts 542 PSL | 71% (383/542) 70% (380/542) PLD 74% (401/542) CID | 66% (356/542) 66% (356/542) PLD 66% (357/542) CID | 5% 4% 8%
Weighted mean difference for studies (range of mean differences; No. studies) | | −0.6% (−5 to 5%; 2 studies)5,6
Weighted mean difference for PLD studies (range of mean differences; No. studies) | | −0.2% (−4 to 4%; 2 studies)5,6
B. Live interactive studies
No studies

#### Conclusion

While overall rates of management accuracy were equivalent (±10%), for malignant and premalignant lesions, rates for teledermatology and teledermatoscopy were inferior to usual care; caution is recommended when using teledermatology in these cases. Because only two studies reported management accuracy, these results may be difficult to generalize to other populations and study settings.

### QUESTION 2b. How does the concordance of teledermatology compare to usual care (in-person dermatology) for clinical management of skin conditions?

(See Table 6, Figures 7a and 7b)

#### SAF Studies

Fourteen SAF teledermatology studies reported management concordance (percent agreement n=13, kappa n=3, sensitivity and specificity n=2). 7,9,10,12,13,15,16,23,26,31,42,43,45,46 Two studies evaluated concordance of the triage management decision of “refer or not refer” for pigmented skin lesions31 or skin lesions;13 percent concordance was 80%^31^ and 61%^13^ for these two studies yielding a weighted average of 75.3% (809/1075). Three studies (in four publications) evaluated concordance for the diagnostic procedure decision “biopsy or no biopsy” and found concordance rates of 100%^23^ and 95%^43^ for skin lesions (weighted average of 98.5%, 68/69) and 76% for a variety of skin conditions.26.^27^ Several studies did not describe management options but reported percent concordance rates of 55% to 94% (Figure 7a).7,12,15,16,45,46 Two studies evaluated concordance rates for three different management options; these rates were 96%^9^ and 72%.42

Table 6 Studies Reporting Management Concordance between Teledermatology and Usual Care (In-Person Dermatology) (KQ2b)

Study | Percent concordant | Kappa statistic | Sensitivity and Specificity
A. Store and forward pigmented skin lesion studies (n=2)
Di Stefani 2007^9^ 18 Pts 465 PSL | TD1 96% TDSC TD2 96% TDSC Denominator: # of lesions For 3 Management Options (Annual follow-up, Short term follow-up, Biopsy) | TD1 k=0.68 TD2 k=0.70 | NR
Joliffe 2001^31^ 611 Pts 819 PSL | 80% (652/819) Concordance for refer or not refer | NR | Sensitivity=0.69 Specificity=0.82 Calculated on 82% of refer or not refer
B. Store and forward skin lesion studies (n=5)
Ferrandiz 2007^10^ 134 SL (73% NMSC) | NR | k=0.75 (95% CI 0.71, 0.79) Agreement on planned surgical technique | NR
Bowns 2006^13^ 256 Pts 256 SL | 61% (157/256) Concordance for refer or not refer | NR | NR
Mahendran 2005^16^ 163 Pts 163 SL | 55% (90/163) | NR | NR
Shapiro 2004^23^ 49 Pts 49 SL | 100% (49/49) Concordance for biopsy vs. no biopsy | NR | Sensitivity=1.0 (95% CI 0.87, 1.00) Specificity=1.0 (95% CI 0.85, 1.00)
Whited 1998^43^ VA 12 Pts 10 SL | TD1 100% (10/10) TD2 90% (9/10) Concordance for biopsy or no biopsy | NR | NR
C. Store and forward general studies (n=7)
Edison 2008^7^ 110 Pts 110 Conditions | 66% (73/110) (95% CI 58%, 75%) | k=0.62 (95% CI 0.55, 0.69) | NR
Bowns 2006^12^ 92 Pts 92 Conditions | 55% (51/92) | NR | NR
Oakley 2006^15^ 73 Pts 109 Conditions | 82% (208/252) TDSC Denominator: # of responses from up to 38 TDs and 5 CDs, including 2 plastic surgeons | NR | NR
Pak 2003^26^ DoD 404 Pts 404 Conditions | 76% (307/404) Concordance for biopsy or no biopsy | NR | NR
Whited 1999^42^ VA 129 Pts 168 Conditions Denominators for Management Types NR | 3 TDs Medical Therapy: Aggregated: 71%, 75%, 80% Primary: 67%, 68%, 69% Clinical Procedures: Aggregated: 64%, 73%, 74% Primary: 64%, 73%, 74% Diagnostic Tests: Aggregated: 70%, 69%, 69% Primary: 67%, 66%, 68% | NR | NR
Lyon 1997^45^ 90 Pts 90 Conditions | 94% (85/90) CD=resident TD=staff | NR | NR
Zelickson 1997^46^ 29 Pts 30 Conditions | 90% (54/60) Combination of 2–3 TDs | NR | NR
D. Live interactive studies (n=4)
Edison 2008^7^ 110 Pts 110 Conditions | 75% (82/110) (95% CI 66%, 83%) | k=0.71 (95% CI 0.64, 0.78) | NR
Gilmour 1998^48^ 61 Pts 61 Conditions | 72% (44/61) | NR | NR
Loane 1998^56^ 214 Pts 252 Conditions | 64% (160/252) TD also served as CD in 44% of cases | NR | NR
Phillips 1998^52^ 51 Pts 107 SL | 86% (92/107) Concordance for biopsy or no biopsy | k=0.47 Biopsy or no biopsy | NR

Figure 7a Management Concordance of Store and Forward Studies

Figure 7b Management Concordance of Live Interactive Studies

Three studies reported the following kappa statistics: k=0.69 for three management options for 265 pigmented skin lesions in 18 patients;9 k=0.75 for planned surgical technique for 134 skin lesions;10 and k=0.62 for 110 skin conditions.7 Sensitivity/specificity ranged from 0.69/0.82 (refer or not refer31) to 1.0/1.0 (biopsy or no biopsy23).

#### LI Studies

Four LI teledermatology studies reported management concordance.7,48,52,56 A study of 107 skin lesions in 51 patients found a concordance rate of 86% (k=0.47) for the decision “biopsy or no biopsy.”52 Three other studies involving a wide variety of skin conditions found concordance rates of 64%,56 72%,48 and 75%.7 No LI studies reported sensitivity/specificity.

#### Conclusion

Concordance rates for management were moderate to very good for both SAF and LI teledermatology.

## KEY QUESTION 3. How do clinical outcomes (clinical course, satisfaction, quality of life, visits avoided) of teledermatology compare to usual care (in-person dermatology) for skin conditions?

(See Tables 7, 8, and 9)

Table 7 Clinical Course Outcome for Teledermatology Studies (KQ3)

Study Country Number of Subjects for Clinical Course Outcome/Total Number of Subjects Design | Intervention | Clinical Course
Study Country Number of Subjects for Clinical Course Outcome/Total Number of Subjects Design | Intervention | Teledermatology Care | Usual
A. Store and forward systems studies (n=2)
Eminovic 2009^57^ Netherlands N=369 evaluable (total N=605 pts) RCT; general practitioners randomized to TD or UC Clinical outcome assessed at time of CD appointment | Teledermatology group: SAF TD followed by CD visit at 1 month Usual care group: referred for CD visit (approximately 1 month waiting time) | 40/200 (20%) judged to not need CD visit because condition had improved | 7/169 (4%) judged to not need CD visit because condition had improved
Pak 2007^58^ United States VA and DoD N=508/698 Clinical outcome assessed by photographs (baseline compared to four months) | Teledermatology group: baseline SAF TD with repeat imaging at 4 months Usual care group: CD visit (baseline) with imaging for outcome assessment only; repeat imaging at 4 months | 64% improved 33% no change 4% worse n=272 | 65% improved 32% no change 3% worse n=236 (p=0.57)
B. Live interactive studies (n=1)
Granlund 2003^59^ Finland N=29/48 Non-randomized; same dermatologist for TD and UC Clinical outcome assessed via questionnaire at six months (29 of 48 pts responded) | Patients from first clinic had TD consultation Patients from second clinic had CD consultation Both groups: follow-up as needed after initial consultation | 63% ”still suffer from disease” 63% “resolved” n=16 | 85% “still suffer from disease” 23% “resolved” n=13 (p=0.03)

Table 8 Patient Satisfaction and Patient Preference for Teledermatology Studies (KQ3)

Study Country Satisfaction Assessment Number of Patients for this Outcome Preference | Patient Satisfaction | | Preference
Study Country Satisfaction Assessment Number of Patients for this Outcome Preference | Teledermatology | Usual Care | Preference
A. Store and forward systems studies (n=7)
Eminovic 2009^57^ Netherlands RCT - GPs randomized to TD or UC 20/43 items from short-form Patient Satisfaction Questionnaire III (mean score, 5 point scale - 5 indicating greatest satisfaction) N=350/605 (57.8% response rate) | 3.8 n=191 | 3.8 n=159 | NR
Bowns 2006^12^ United Kingdom RCT 51 items from Patient Satisfaction Questionnaire III plus 9 items specific to SAF N=147/208 (70.7% response rate) | satisfied overall: 84% n=80 | satisfied overall: 87% n=67 (p=0.59) | preferred TD over waiting for UC: 76%
Moreno-Ramirez 2005^18^ Spain, Pigmented Lesions Repeated measure design Question “Are you satisfied with this way of being attended by a specialist?” N=219 TD; 108/219 “selected” for additional UC | very satisfied: 86% n=219 | very satisfied: 98% n=108 (all had TD before UC) | NR
Whited 2004^60^ United States; Durham, NC VAMC RCT Telephone Survey UC: Visit-Specific Satisfaction Questionnaire TD: Related questions plus specific TD items BOTH: 5 point scale (Excellent to Poor) N=194/275 (70.5% response rate) | excellent or very good: 79% n=101 | excellent or very good: 78% n=93 | preferred TD over UC: 42% preferred UC over TD: 37%
Weinstock 2001^61^ United States; Togus, Maine VAMC TD Cohort Telephone Survey (10 questions) 5 point scale (Excellent to Poor) Mean 14 months after TD (range 2.5–30.5) N=100/148 (67.6% response rate) randomly selected from 1030 consults | excellent or good: 42% ability of TD to treat skin disease: good/excellent 41% fair/poor 46% | no comparison group | NR
Williams 2001^62,63^ United Kingdom TD Cohort Survey of 15 items developed for SAF TD 5 point scale (strongly disagree to strongly agree) N=123/141 (87.2% response rate) | “happy” with TD: 93% | no comparison group | prefer UC to TD: 40% believed TD as good as UC: 68%
Pak 1999^64^ United States, DoD TD Cohort Survey (details NR) at baseline and 4–6 weeks N=77/100 (baseline; 77% response rate) N= 55/100 (4–6 week; 55% response rate) | baseline: satisfied with TD: “most” 4–6 weeks: satisfied with TD: 64% | no comparison group | at 4–6 weeks: prefer UC: 38% prefer TD to waiting for UC: 42%
B. Live interactive studies (n=9)
Granlund 2003^59^ Finland Open, non-randomized TD vs. UC Survey of 5 questions: Completed after encounter and 6 months 5 point scale (very good to very bad) Linear analog scale of 0 to 10 Completed after encounter and 6 months N=48 immediately after encounter N=29 at 6 months | satisfied with TD: 96% n=23 Linear analog scale: Median=9.6 after consultation Mean=7.4 at 6 months n=16 | satisfied with UC: 83% n=25 (p=0.03) Linear analog scale: Median=9.0 after consultation (p=0.03) Mean=6.6 at 6 months (p>0.05) n=13 | NR
Baba 2005^17^ Turkey Combined SAF + LI Cohort Questions: 1) Acceptance of TD or UC 2) Need for LI in addition to SAF N=228 | overall satisfaction NR | no comparison group | would accept TD: 85% (of these, 82% felt LI+SAF was needed rather than just SAF)
Hicks 2003^65^ United States TD Cohort Survey of 8 questions: Completed after each visit, >1 survey per pt 7-point scale (very unsatisfied to very satisfied) N=321 TD pts | very satisfied or satisfied: 88% n=258 | no comparison group | felt TD much better/better than UC: 69% n=255
Nordal 2001^47^ Norway Repeated measures design Survey of 9 items: 4 point scale (very satisfied to unsatisfied) N=116/121 (95.9% response rate) | very satisfied with TD: 44% unsatisfied with TD: 10% | no comparison group | for a future dermatology consult: prefer TD: 38% prefer UC: 28% indifferent: 34% general preference: prefer TD: 18% prefer CD: 16% indifferent: 66%
Lamminen 2000^66^ Finland TD Cohort Survey (details NR) N=25 | TD “excellent or good”: 92% | no comparison group | NR
Gilmour 1998^48^ United Kingdom Repeated measures design Survey of 16 items: 5 point scale (strongly disagree to strongly agree) N=122/126 (96.8% response) | overall satisfaction NR | no comparison group | prefer TD: 38% prefer UC: 42% TD as good as UC: 43%
Lowitt 1998^51^ United States, Baltimore VAMC Repeated measures design Survey of 7 items: 4 point scale (strongly disagree to strongly agree) N=124/139 (89.2% response rate) | overall satisfaction NR | overall satisfaction NR more “strongly agree” responses for UC vs. more “agree” responses for TD (p=0.001) | “most” prefer TD close to home rather than UC 2 hours away
Loane 1998^67^ Northern Ireland Repeated measures design Survey of 15 items: 5 point scale (strongly disagree to strongly agree) N=292/334 (87.4% response rate) | overall satisfaction NR | overall satisfaction NR | prefer TD: 41% prefer UC: 43% TD as good as UC: 66%
Oakley 1997^53^ New Zealand Repeated measures design Survey (details NR): 5 point scale (strongly disagree to strongly agree) N=98/104 (94.2% response rate) | overall satisfaction NR | overall satisfaction NR | TD as good as UC: 54% undecided: 31%

Table 9 Time to Treatment and Clinic Dermatology Visits Avoided for Teledermatology Studies (KQ3)

Study | Time to Treatment (Average) | CD Visits Avoided^*^
A. Store and forward systems studies (n=11)
Eminovic 2009^57^ Netherlands Cluster RCT N=369/605 | NR | CD visits “preventable” for: TD 39.0% (N=200) UC 18.3% (N=169) Difference 20.7% (95% CI 8.5, 32.9)
Hsiao 2008^68^ United States Retrospective review of veterans treated for skin cancer N=149/169 46% UC, 54% TD | Consult to (days): Opinion (TD or CD): TD 4 vs. UC 48 (p<0.001) Biopsy: TD 38 vs. UC 57 (p=0.034) Surgery: TD 104 vs. UC 125 (p=0.006) | Mean number of CD visits: TD 0.98 vs. UC 1.13 (p=0.02) NOTE: 14% of TD did not require any CD visits prior to surgery; all UC required ≥1 visit
Ferrandiz 2007^10^ Spain Pilot study of SL needing regular surgical excision N=226 (134 TD compared to random sample of 92 UC | Consult to surgery (days): TD 26.1 vs. UC 60.6 (p<0.001) | TD: 1 CD visit needed UC: ≥2 CD visits needed Difference: ≥1 visit
Moreno-Ramirez 2007^11^ Spain Repeated Measure, Historical Control N=2539 (2009 TD compared to 530 UC | Consult to CD clinic (days): TD 12.3 vs. UC 88.6 (p<0.001) Time for TD results 61.1 hrs NOTE: N unclear for this outcome | 51.2% (n=1029) of TD did not need CD visit
Bowns 2006^12^ United Kingdom RCT N=165/208 | Consult to opinion (days): TD 13 (n=85) vs. UC 67 (n=72) p<0.0001 | No follow-up visits needed: TD 66% vs. UC 38% (p=0.0003)
Knol 2006^72^ Netherlands N=306 intent to refer consultations and 505 TD No comparison group | NR | 53.3% (n=163) did not need CD
Mahendran 2005^16^ United Kingdom Repeated Measure N=163 | NR | 12.8% (n=21) did not need CD (reassurance only) 33.1% (n=54) did not need CD consult visit but did need CD surgery
Moreno-Ramirez 2005^18^ Spain Cohort, PSL N=219 | Time for TD results 44 hrs | 51% (n=111) did not need CD
Whited 2002^69^ United States RCT of Veterans N=275 (TD=135, UC=127) | Consult to definitive intervention (days, median): Intent to Treat: TD 41 vs. UC 127 p=0.0001 Actual Visit: TD 50 vs. UC 137.5 p=0.0027 | 18.5% of TD did not need CD
Taylor 2001^33^ United Kingdom TD Reliability Study N=188/194 | NR | 31% of TD did not need CD (based on 376 assessments, 188 cases X 2 consultants) NOTE: CD diagnosis differed from TD diagnosis in 14% of these 188 cases
Pak 1999^64^ United States Department of Defense Cohort, no comparison group N=100 | NR | 45% did not need CD
B. Live interactive studies (n=3)
Loane 2001^70^ United Kingdom RCT TD vs. UC N=274 (126 TD, 148 UC) | NR | 44% of TD and 30% of UC did not need follow-up visit
Wooton 2000^71^ United Kingdom RCT TD vs. UC N=204 ( 102 TD, 102 UC) | NR | 54% of TD and 55% of UC did not need follow-up visit
Lamminen 2000^66^ Finland Cohort, TD N=25 | NR | 72% did not need follow-up visit

* Does not include TD visit(s). Number of CD visits avoided

### Clinical Outcomes

We identified three studies that reported clinical course for patients evaluated with either teledermatology or usual care (in-person dermatology) (Table 7).57,58,59 Although two of the studies suggested that clinical course is more favorable following teledermatology, the three studies used different methods for determining clinical course and assessed clinical course at different time points.

Eminovic et al.57 reported a notable difference in the percentage of patients improved at one month after referral in the teledermatology group (20%) compared to the usual care group (4%). The assessment was done by a dermatologist during an in-person dermatology consultation. However, it is important to note that the teledermatology group was treated during the one month period, as needed, based on the results of the teledermatology consultation while the usual care group had yet to see a dermatologist. In the Pak et al.58 study involving DOD and veterans, the assessment was done for both groups at four months after the initial visit (either teledermatology or in-person dermatology) using photographic images. There was no significant difference in clinical course rating (improved, no change, or worse) between the two groups. Granlund et al.59 assessed outcomes at six months using a questionnaire. The response rate was 60%. A significantly higher percentage of teledermatology patients reported that their condition had resolved (63% vs. 23%, p=0.03).

### Patient Satisfaction

Seven SAF and four LI studies reported patient satisfaction (Table 8). Assessment tools ranged from a single question to surveys with over 50 items. As a result of the wide discrepancy in assessments used, we focused our report on overall satisfaction measures rather than satisfaction with specific elements of teledermatology or usual care (in-person dermatology).

SAF Studies: In the four SAF studies that included both teledermatology and usual care groups, satisfaction ratings were comparable with a mean satisfaction rating of 3.8 out of 5,^57^ or greater than 75% of patients reporting satisfaction with both teledermatology and usual care.12,18,60 In the three studies with no comparison group, teledermatology was rated as “excellent” or “good” by 42% of the patients;61 93% reported they were “happy” with teledermatology;62,63 and at 4 to 6 weeks after teledermatology, 64% reported they were satisfied.64 Three of the studies included VA or DoD populations.60,61,64

LI Studies: Four LI studies reported patient satisfaction. In the one study that included teledermatology and usual care groups (non-randomized), a significantly greater number of patients (96% vs. 83%, p=0.03) reported they were satisfied with teledermatology than with usual care.59 The median satisfaction rating (on a scale of 0 to 10) was also higher for the teledermatology group (9.6 vs. 9.0, p=0.03). Of the three studies without a comparison group, the reported satisfaction ratings were 44%,47 88%,65 and 92%.66 Only one of these studies was completed in the United States.65

Overall: Of the five studies that included both teledermatology (either SAF or LI) and usual care groups, patients expressed comparable levels of satisfaction in three of the studies (all of which were randomized, controlled trials; one included a veteran population).12,57,60 One non-randomized study reported greater satisfaction with teledermatology.59 One repeated measures study reported greater satisfaction with usual care, however, the usual care patients in that study had already been seen via SAF teledermatology.18 Response rates for the satisfaction assessments ranged from 58% to 100%.

### Patient Preference

Four SAF and eight LI studies reported patient preference (Table 8). A total of four of these studies (2 SAF, 2 LI) were conducted in the United States.

SAF Studies: With the exception of one study that reported that 76% of patients preferred teledermatology over waiting for a usual care appointment,12 preferences for teledermatology or usual care were similar. In one VA study, 42% preferred teledermatology over usual care while 37% preferred usual care over teledermatology.60 A study from the United Kingdom reported that 40% preferred usual care over teledermatology with 68% responded that teledermatology was “as good as” usual care.62,63 A DoD-based study reported that 42% preferred teledermatology and 38% preferred usual care when asked 4 to 6 weeks after their initial appointment.64

LI Studies: In one study, patients experienced both SAF and LI sessions. Although 85% “accepted” SAF teledermatology, 82% of those patients felt that the LI session was also needed.17 Reported preferences for teledermatology ranged from 69%^65^ to 38%.47,48 Reported preferences for usual care ranged from 28%^47^ to 43%.67 In two studies, approximately one-third of the patients surveyed expressed no preference.47,53 In two studies, teledermatology was rated “as good as” usual care by 54%^53^ and 66%^67^ of patients.

Overall: Preference for teledermatology ranged from 38% to 86%. One study reported slightly higher satisfaction with usual care but 76% of the patients preferred teledermatology over waiting to see a dermatologist.12 A VA study reported that patients were more likely to respond “strongly agree” to statements about satisfaction with usual care and more likely to respond “agree” to statements about satisfaction with teledermatology yet “most” patients preferred a teledermatology appointment rather than driving 2 hours to see a dermatologist.51 It appears that other factors, such as waiting time for a in-person dermatology appointment and the need to travel long distances (involving both expense and time off from work), influence patient preference for usual care or teledermatology.

### Time to Treatment

Four SAF studies and no LI studies addressed the question of time to treatment (Table 9). One study included both time to treatment and time to teledermatology results; one additional study included only time to teledermatology results.

In all four studies, the time to treatment was shorter for patients who were initially seen by teledermatology. Time from general practitioner consult to dermatology clinic (or opinion) was significantly shorter for teledermatology patients compared to usual care patients in the three studies that reported this outcome11,12,68 with the difference ranging from 44 days to 76.3 days (all p<0.001). Time to biopsy was 19 days shorter (p=0.03).68 Time to surgery or definitive intervention was significantly shorter in the three studies that reported this outcome.10,68,69 The difference ranged from 21 to 86 days (all p<0.01). Two of these studies68,69 were conducted at VA medical centers. It is important to note that although times to treatment experienced by teledermatology patients in the VA studies were shorter than those for usual care patients, the reported times are not reflective of current VA practices; all veterans now are scheduled within 30 days. Two studies reported time to teledermatology results. Mean times were 61.1 hours11 and 44 hours.18

### Clinic Dermatology Visits Avoided

The number of in-person dermatology visits avoided was reported in 11 SAF and 3 LI studies (Table 9). Two SAF studies reported the number of dermatology visits required. Teledermatology patients required a mean of 0.98 visits in one study68 and 1 visit in another study.10 In the same two studies, usual care patients required a mean of 1.13 or at least 2 visits, respectively.

Two SAF studies reported the percentage of patients who did not require a dermatology clinic visit (“preventable” visits) following teledermatology compared to usual care patients. The differences between groups were 20.7% (39% teledermatology vs. 18.3% usual care)57 and 28% (66% teledermatology vs. 38% usual care).12 Two live interactive studies reported a similar outcome with a difference of 14% (44% teledermatology vs. 30% usual care) in one study70 and a difference favoring usual care of 1% (54% teledermatology vs. 55% usual care).71

Seven additional SAF studies and one additional LI study reported visits avoided with no comparison group. The percentage of visits avoided ranged from 12.8% to 72%.11,16,18,33,64,66,69,72 The study that reported 12.8% clinic dermatology visits avoided also reported that 33.1% required clinic dermatology surgery.16

### Conclusions

There was insufficient evidence to conclude whether teledermatology had an effect on clinical course, although a VA/DoD study with over 500 patients reported comparable outcomes. Patient overall satisfaction with and preference for teledermatology or usual care were comparable in VA/DoD and other studies. Patients noted waiting time for an appointment and travel time/distance as factors when considering preference. Time to treatment was significantly shorter and clinic dermatology visits can be avoided when patients have an initial teledermatology visit.

## KEY QUESTION 4. How does the cost of teledermatology compare to usual care (in-person dermatology)?

(See Table 10)

Cost data were reported in three studies involving SAF teledermatology, six studies of LI teledermatology, and one study that included both SAF and LI teledermatology (Table 10). Due to differences in factors included in cost assessments and the various perspectives (societal, health service, or patient), it was difficult to summarize these findings.

Table 10 Teledermatology Studies Reporting Cost Outcomes (KQ4)

Author/Year/Country Funding Design | Participants Age, race, gender Skin Conditions | Sites Providers Assumptions | Cost Outcomes/Utilization Outcomes (US$, except as noted)
Store and Forward vs. Usual Care (N=3)
Whited 2003^73^ U.S. Veterans VA HSR&D RCT TD vs. UC | N=275 (135 TD, 140 UC) age: NR race: NR gender: NR Conditions: NR | On-site primary care clinic and on- site dermatology clinic Providers: primarily dermatology residents Micro-costing approach, VA perspective | -Average cost ($) per pt (base-case):
Whited 2003^73^ U.S. Veterans VA HSR&D RCT TD vs. UC | N=275 (135 TD, 140 UC) age: NR race: NR gender: NR Conditions: NR | On-site primary care clinic and on- site dermatology clinic Providers: primarily dermatology residents Micro-costing approach, VA perspective | TD: 36.40 | UC: 21.40
Whited 2003^73^ U.S. Veterans VA HSR&D RCT TD vs. UC | N=275 (135 TD, 140 UC) age: NR race: NR gender: NR Conditions: NR | On-site primary care clinic and on- site dermatology clinic Providers: primarily dermatology residents Micro-costing approach, VA perspective | Incremental cost per pt: 15.00 (sensitivity analysis range: 10.50 to 15.00) -Median time to initial definitive intervention:
Whited 2003^73^ U.S. Veterans VA HSR&D RCT TD vs. UC | N=275 (135 TD, 140 UC) age: NR race: NR gender: NR Conditions: NR | On-site primary care clinic and on- site dermatology clinic Providers: primarily dermatology residents Micro-costing approach, VA perspective | TD: 50.0 days | UC: 137.5 days
Whited 2003^73^ U.S. Veterans VA HSR&D RCT TD vs. UC | N=275 (135 TD, 140 UC) age: NR race: NR gender: NR Conditions: NR | On-site primary care clinic and on- site dermatology clinic Providers: primarily dermatology residents Micro-costing approach, VA perspective | Incremental effectiveness: 87.5 days Incremental cost-effectiveness ratio for TD: $0.17 per pt per day (sensitivity analysis range: $0.12 to $0.17) Conclusion: TD not cost-saving but was cost-effective for decreasing time to initial definitive dermatological care
Pak 2009^74^ U.S. Army Personnel U.S. Army Telemedicine and Advanced Technology Research Center RCT TD vs. UC | N=698 (351 TD, 347 UC) age: NR race: NR gender: NR Conditions: NR | Military primary care and dermatology clinics Providers: NR Cost-minimization, DoD perspective | -Costs ($, average per pt) | TD | | UC
Pak 2009^74^ U.S. Army Personnel U.S. Army Telemedicine and Advanced Technology Research Center RCT TD vs. UC | N=698 (351 TD, 347 UC) age: NR race: NR gender: NR Conditions: NR | Military primary care and dermatology clinics Providers: NR Cost-minimization, DoD perspective | Total Direct | 103,043 (294) | | 98,365 (283)
Pak 2009^74^ U.S. Army Personnel U.S. Army Telemedicine and Advanced Technology Research Center RCT TD vs. UC | N=698 (351 TD, 347 UC) age: NR race: NR gender: NR Conditions: NR | Military primary care and dermatology clinics Providers: NR Cost-minimization, DoD perspective | Lost Productivity | 16,359 (47) | | 30,768 (89)
Pak 2009^74^ U.S. Army Personnel U.S. Army Telemedicine and Advanced Technology Research Center RCT TD vs. UC | N=698 (351 TD, 347 UC) age: NR race: NR gender: NR Conditions: NR | Military primary care and dermatology clinics Providers: NR Cost-minimization, DoD perspective | Total Cost | 119,402 (340) | | 129,133 (372)
Pak 2009^74^ U.S. Army Personnel U.S. Army Telemedicine and Advanced Technology Research Center RCT TD vs. UC | N=698 (351 TD, 347 UC) age: NR race: NR gender: NR Conditions: NR | Military primary care and dermatology clinics Providers: NR Cost-minimization, DoD perspective | Conclusion: TD cost-saving, if lost productivity is considered
Moreno-Ramirez 2009^75^ Spain Instituto Carlos III Non-randomized comparison of consecutive TD and UC pts | N=4018 (2009 TD, 2009 UC) age: NR race: NR gender: NR Conditions: suspected skin cancer | 12 primary care clinics/1 central skin cancer clinic Providers: NR Societal perspective | -Waiting interval for skin cancer clinic:
Moreno-Ramirez 2009^75^ Spain Instituto Carlos III Non-randomized comparison of consecutive TD and UC pts | N=4018 (2009 TD, 2009 UC) age: NR race: NR gender: NR Conditions: suspected skin cancer | 12 primary care clinics/1 central skin cancer clinic Providers: NR Societal perspective | TD: 12.3 days | UC: 88.6 days
Moreno-Ramirez 2009^75^ Spain Instituto Carlos III Non-randomized comparison of consecutive TD and UC pts | N=4018 (2009 TD, 2009 UC) age: NR race: NR gender: NR Conditions: suspected skin cancer | 12 primary care clinics/1 central skin cancer clinic Providers: NR Societal perspective | Incremental effectiveness 76.3 days -Unit cost ($) per pt:
Moreno-Ramirez 2009^75^ Spain Instituto Carlos III Non-randomized comparison of consecutive TD and UC pts | N=4018 (2009 TD, 2009 UC) age: NR race: NR gender: NR Conditions: suspected skin cancer | 12 primary care clinics/1 central skin cancer clinic Providers: NR Societal perspective | TD: 119.67 | UC: 194.06 (p<0.005)
Moreno-Ramirez 2009^75^ Spain Instituto Carlos III Non-randomized comparison of consecutive TD and UC pts | N=4018 (2009 TD, 2009 UC) age: NR race: NR gender: NR Conditions: suspected skin cancer | 12 primary care clinics/1 central skin cancer clinic Providers: NR Societal perspective | Incremental cost savings of TD $74.39
Moreno-Ramirez 2009^75^ Spain Instituto Carlos III Non-randomized comparison of consecutive TD and UC pts | N=4018 (2009 TD, 2009 UC) age: NR race: NR gender: NR Conditions: suspected skin cancer | 12 primary care clinics/1 central skin cancer clinic Providers: NR Societal perspective | -Cost-effectiveness: $0.98 saved per waiting day avoided by | | | | TD
Moreno-Ramirez 2009^75^ Spain Instituto Carlos III Non-randomized comparison of consecutive TD and UC pts | N=4018 (2009 TD, 2009 UC) age: NR race: NR gender: NR Conditions: suspected skin cancer | 12 primary care clinics/1 central skin cancer clinic Providers: NR Societal perspective | Conclusion: SAF TD is cost-effective for referrals to skin cancer clinic
Store and Forward vs. Live Interactive (N=1)
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | -Dermatologist consultation time (mean):
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | SAF: 1.6 min | | LI: 15.7 min
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | -Total pt time (wait, consult, travel) (mean):
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | SAF: 41.5 min | | LI: 52.2 min
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | -Variable costs per pt | [underlined: SAF] | [underlined: LI]
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | Dermatologist | £4.00 | £39.25
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | GP | £9.50 | £29.83
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | Pt time off work | £4.76 | £5.99
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | Pt travel (all local) | £1.89 | £1.89
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | Total | £20.15 | £76.96
Loane^†^ 2000^80^ United Kingdom NHS R&D, Southern Health and Social Services Board, Glaxo, Steifel Repeated measure both SAF and LI TD Anonymous economic questionnaire after LI consultation | N=96/102 randomized to TD (see Wootton 2000) age: mean=38.9 years race: NR gender: 47% male Conditions: Most common - eczema, psoriasis, acne, and tumors | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: 2 dermatologists (1 for SAF and 1 for LI) | -Fixed costs SAF: £6.75 LI: £124.92 -Savings with LI (20% non-referral savings): £9.74 -Benefits with LI (GP training): £60.04 -Net societal costs SAF: £29.90 LI: £132.10 Conclusion: SAF cheaper, but less clinically efficient, than LI
Live Interactive vs. Usual Care (N=6)
Burgiss 1997^76^ U.S. Funding: NR Before and after TD comparison | N=87 (119 visits) age: NR race: NR gender: NR Conditions: dermatitis, infectious, acnei-form, papulosquamous, tumors | 2 rural primary care centers and university dermatology clinic Providers: 1 dermatologist | -Total Costs $ (per Pt) | [underlined: Primary care]* | | [underlined: TD]
Burgiss 1997^76^ U.S. Funding: NR Before and after TD comparison | N=87 (119 visits) age: NR race: NR gender: NR Conditions: dermatitis, infectious, acnei-form, papulosquamous, tumors | 2 rural primary care centers and university dermatology clinic Providers: 1 dermatologist | Provider | 8,848 (102) | | 5,236 (60)
Burgiss 1997^76^ U.S. Funding: NR Before and after TD comparison | N=87 (119 visits) age: NR race: NR gender: NR Conditions: dermatitis, infectious, acnei-form, papulosquamous, tumors | 2 rural primary care centers and university dermatology clinic Providers: 1 dermatologist | Diagnostic evaluation | 9,367 (108) | | 3,031 (35)
Burgiss 1997^76^ U.S. Funding: NR Before and after TD comparison | N=87 (119 visits) age: NR race: NR gender: NR Conditions: dermatitis, infectious, acnei-form, papulosquamous, tumors | 2 rural primary care centers and university dermatology clinic Providers: 1 dermatologist | Medication | 7,388 (85) | | 3,969 (46)
Burgiss 1997^76^ U.S. Funding: NR Before and after TD comparison | N=87 (119 visits) age: NR race: NR gender: NR Conditions: dermatitis, infectious, acnei-form, papulosquamous, tumors | 2 rural primary care centers and university dermatology clinic Providers: 1 dermatologist | Total | 25,603 (294) | | 12,236 (141)
Burgiss 1997^76^ U.S. Funding: NR Before and after TD comparison | N=87 (119 visits) age: NR race: NR gender: NR Conditions: dermatitis, infectious, acnei-form, papulosquamous, tumors | 2 rural primary care centers and university dermatology clinic Providers: 1 dermatologist | *cost of care for pt prior to TD consultation Conclusion: TD can decrease costs of dermatological care
Wootton^†^ 2000^71^ United Kingdom UK Multicentre Teledermatology Trial NHS R&D; Southern Health and Social Service Board, Glaxo, Steifel RCT TD vs. UC Anonymous economic questionnaire after TD consultation | N=169/204 (102 TD, 102 UC) age: mean=38.6 yrs race: NR gender: 42% male Conditions: NR | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: NR | -Costs per Pt | [underlined: TD] | | [underlined: UC]
| N=169/204 (102 TD, 102 UC) age: mean=38.6 yrs race: NR gender: 42% male Conditions: NR | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: NR | Variable costs | £76.96 | | £48.73
| N=169/204 (102 TD, 102 UC) age: mean=38.6 yrs race: NR gender: 42% male Conditions: NR | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: NR | Fixed costs | £124.92 | | £0.00
| N=169/204 (102 TD, 102 UC) age: mean=38.6 yrs race: NR gender: 42% male Conditions: NR | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: NR | Savings | £9.74 | | £0.00
| N=169/204 (102 TD, 102 UC) age: mean=38.6 yrs race: NR gender: 42% male Conditions: NR | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: NR | Benefits | £60.04 | | £0.00
| N=169/204 (102 TD, 102 UC) age: mean=38.6 yrs race: NR gender: 42% male Conditions: NR | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: NR | Net societal cost | £132.10 | | £48.73
| N=169/204 (102 TD, 102 UC) age: mean=38.6 yrs race: NR gender: 42% male Conditions: NR | 4 primary care centers (2 rural, 2 urban) and 2 dermatology centers Providers: NR | Conclusion: TD not cost-effective in setting evaluated (average distance to dermatology clinic 26km); TD would be cost-effective if distance >78km
Loane 2001^77^ New Zealand New Zealand Ministry of Health and Health Informatics Foundation, V-Tel, B&H Ltd, Digital Equipment Corporation, Leo RCT TD vs. UC Patient questionnaire | N=203 (109 TD, 94 UC) age: mean=41 yrs (14% minors/in school) race: NR gender: 48% male Conditions: NR | 2 rural primary care centers and 1 dermatology department Providers: NR Societal perspective | -Costs ($): | [underlined: TD] | | [underlined: UC]
Loane 2001^77^ New Zealand New Zealand Ministry of Health and Health Informatics Foundation, V-Tel, B&H Ltd, Digital Equipment Corporation, Leo RCT TD vs. UC Patient questionnaire | N=203 (109 TD, 94 UC) age: mean=41 yrs (14% minors/in school) race: NR gender: 48% male Conditions: NR | 2 rural primary care centers and 1 dermatology department Providers: NR Societal perspective | Fixed Costs | 7974.05 | | 0.00
Loane 2001^77^ New Zealand New Zealand Ministry of Health and Health Informatics Foundation, V-Tel, B&H Ltd, Digital Equipment Corporation, Leo RCT TD vs. UC Patient questionnaire | N=203 (109 TD, 94 UC) age: mean=41 yrs (14% minors/in school) race: NR gender: 48% male Conditions: NR | 2 rural primary care centers and 1 dermatology department Providers: NR Societal perspective | Variable Costs | 7481.45 | | 13,536.60
Loane 2001^77^ New Zealand New Zealand Ministry of Health and Health Informatics Foundation, V-Tel, B&H Ltd, Digital Equipment Corporation, Leo RCT TD vs. UC Patient questionnaire | N=203 (109 TD, 94 UC) age: mean=41 yrs (14% minors/in school) race: NR gender: 48% male Conditions: NR | 2 rural primary care centers and 1 dermatology department Providers: NR Societal perspective | Total | 15,455.50 | | 13,536.60
Loane 2001^77^ New Zealand New Zealand Ministry of Health and Health Informatics Foundation, V-Tel, B&H Ltd, Digital Equipment Corporation, Leo RCT TD vs. UC Patient questionnaire | N=203 (109 TD, 94 UC) age: mean=41 yrs (14% minors/in school) race: NR gender: 48% male Conditions: NR | 2 rural primary care centers and 1 dermatology department Providers: NR Societal perspective | Unit Cost | 125.65 | | 127.71
Loane 2001^77^ New Zealand New Zealand Ministry of Health and Health Informatics Foundation, V-Tel, B&H Ltd, Digital Equipment Corporation, Leo RCT TD vs. UC Patient questionnaire | N=203 (109 TD, 94 UC) age: mean=41 yrs (14% minors/in school) race: NR gender: 48% male Conditions: NR | 2 rural primary care centers and 1 dermatology department Providers: NR Societal perspective | Conclusion: From societal perspective, TD more cost-efficient than UC
Bergmo 2000^78^ Norway Funding: NR Case Series comparison of TD to 3 alternatives: 1. combination of pt travel and visiting dermatologist 2. pt travel to central dermatologist 3. hiring local dermatologist | N=375 TD pts (actual workload for 1 yr) age: NR race: NR gender: NR Conditions: NR | 1 primary care clinic and 1 central dermatology clinic Providers: NR Assumed health out- comes for TD = UC Societal and health-care sector perspective | -Fixed Costs ($)
| N=375 TD pts (actual workload for 1 yr) age: NR race: NR gender: NR Conditions: NR | 1 primary care clinic and 1 central dermatology clinic Providers: NR Assumed health out- comes for TD = UC Societal and health-care sector perspective | TD: 43,866.35 | Pt Travel/Visiting: 35,052.60
| N=375 TD pts (actual workload for 1 yr) age: NR race: NR gender: NR Conditions: NR | 1 primary care clinic and 1 central dermatology clinic Providers: NR Assumed health out- comes for TD = UC Societal and health-care sector perspective | Pt Travel: 0 | Local Dermatologist: 105,452.60
| N=375 TD pts (actual workload for 1 yr) age: NR race: NR gender: NR Conditions: NR | 1 primary care clinic and 1 central dermatology clinic Providers: NR Assumed health out- comes for TD = UC Societal and health-care sector perspective | -Variable Costs ($) per Pt
| N=375 TD pts (actual workload for 1 yr) age: NR race: NR gender: NR Conditions: NR | 1 primary care clinic and 1 central dermatology clinic Providers: NR Assumed health out- comes for TD = UC Societal and health-care sector perspective | TD: 21.12 | Pt Travel/Visiting: 66.33 for 1st 240 pts*
| N=375 TD pts (actual workload for 1 yr) age: NR race: NR gender: NR Conditions: NR | 1 primary care clinic and 1 central dermatology clinic Providers: NR Assumed health out- comes for TD = UC Societal and health-care sector perspective | Pt Travel: 479.60 | Local Dermatologist: 0
| N=375 TD pts (actual workload for 1 yr) age: NR race: NR gender: NR Conditions: NR | 1 primary care clinic and 1 central dermatology clinic Providers: NR Assumed health out- comes for TD = UC Societal and health-care sector perspective | *Maximum workload for visiting dermatologist - 240 pts; remaining pts travel to clinic at cost of $339.90 per pt Conclusion: TD was less costly than the three alternatives if >195 pts per year
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | -Total Costs/Benefits($): | [underlined: Urban] | | [underlined: Rural]
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | | [underlined: TD] | [underlined: UC] | [underlined: TD] | [underlined: UC]
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | Variable | 7025 | 7226 | 4747 | 3062
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | Fixed | 10527 | 0 | 8605 | 0
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | Total | 17552 | 7226 | 13352 | 3062
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | Savings | 1084 | 0 | 459 | 0
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | Societal* | 16468 | 7226 | 12893 | 3062
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | Marginal** | 77 | 69 | 88 | 71
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | Unit*** | 214 | 69 | 263 | 71
Loane^†^ 2001^70^ UK Funding: NR RCT TD vs. UC Patient questionnaire after each visit | N=274 pts (126 TD, 148 UC) 254/413 (62%) questionnaires completed age: mean=39.7 years race: NR gender: 44% male TD pts: 61% urban, 39% rural UC pts: 71% urban, 29% rural Conditions: NR | 1 urban and 1 rural primary care clinic and 1 dermatology department Providers: General practitioners and dermatologists Health service and pt perspectives | *(Fixed+Variable)-(Savings) **(Variable-Savings)/(#Pts) ***(Societal)/(#Pts) Conclusion: Overall, total costs higher for TD than UC Sensitivity analysis found that for rural areas, TD costs < UC
Armstrong 2007^79^ U.S. Funding: NR Non-randomized comparison of TD and UC visits | N=451 TD visits (301 new, 150 follow- up) and 47,434 UC visits age: NR race: NR gender: NR Conditions: Top 5 conditions: actinic keratosis, eczema, acne, benign neoplasm, viral infection | 1 Primary care center and 1 dermatology clinic Providers: 1 nurse practitioner (trained in dermatologic procedures); 1 dermatologist Provider perspective; cost-minimization | -Costs ($) per hour | [underlined: TD] | | [underlined: UC]
Armstrong 2007^79^ U.S. Funding: NR Non-randomized comparison of TD and UC visits | N=451 TD visits (301 new, 150 follow- up) and 47,434 UC visits age: NR race: NR gender: NR Conditions: Top 5 conditions: actinic keratosis, eczema, acne, benign neoplasm, viral infection | 1 Primary care center and 1 dermatology clinic Providers: 1 nurse practitioner (trained in dermatologic procedures); 1 dermatologist Provider perspective; cost-minimization | TD equipment | 4.75 | | 0.00
Armstrong 2007^79^ U.S. Funding: NR Non-randomized comparison of TD and UC visits | N=451 TD visits (301 new, 150 follow- up) and 47,434 UC visits age: NR race: NR gender: NR Conditions: Top 5 conditions: actinic keratosis, eczema, acne, benign neoplasm, viral infection | 1 Primary care center and 1 dermatology clinic Providers: 1 nurse practitioner (trained in dermatologic procedures); 1 dermatologist Provider perspective; cost-minimization | Facility and personnel | 143.88 | | 193.04
Armstrong 2007^79^ U.S. Funding: NR Non-randomized comparison of TD and UC visits | N=451 TD visits (301 new, 150 follow- up) and 47,434 UC visits age: NR race: NR gender: NR Conditions: Top 5 conditions: actinic keratosis, eczema, acne, benign neoplasm, viral infection | 1 Primary care center and 1 dermatology clinic Providers: 1 nurse practitioner (trained in dermatologic procedures); 1 dermatologist Provider perspective; cost-minimization | Physician compensation | 125.00 | | 153.00
Armstrong 2007^79^ U.S. Funding: NR Non-randomized comparison of TD and UC visits | N=451 TD visits (301 new, 150 follow- up) and 47,434 UC visits age: NR race: NR gender: NR Conditions: Top 5 conditions: actinic keratosis, eczema, acne, benign neoplasm, viral infection | 1 Primary care center and 1 dermatology clinic Providers: 1 nurse practitioner (trained in dermatologic procedures); 1 dermatologist Provider perspective; cost-minimization | Total | 273.63 | | 346.04
Armstrong 2007^79^ U.S. Funding: NR Non-randomized comparison of TD and UC visits | N=451 TD visits (301 new, 150 follow- up) and 47,434 UC visits age: NR race: NR gender: NR Conditions: Top 5 conditions: actinic keratosis, eczema, acne, benign neoplasm, viral infection | 1 Primary care center and 1 dermatology clinic Providers: 1 nurse practitioner (trained in dermatologic procedures); 1 dermatologist Provider perspective; cost-minimization | Conclusion: Hourly costs higher for UC than TD One-way Sensitivity Analyses found TD = UC costs if: a. technology cost $44/hr b. physician compensation was $197/hr c. clinic space cost was $57/hr (rather than $12.50-TD and $100-UC) Reimbursement for TD: per visit=$122, per hour=$487

† UK Multicentre Teledermatology Trial

1 Post-operative wound care, and chronic dermatitis.

SAF Studies: Whited et al.73 used a micro-costing approach with a VA perspective and found that teledermatology was cost-effective but not cost-saving for decreasing time to initial definitive dermatologic care. It was assumed that VA centers had both on-site primary care and dermatology clinics. Definitive care was achieved in 50 days using teledermatology compared to 138 days with usual care. The long-duration to achieve definitive dermatologic care, particularly for the usual care population, is no longer consistent with current VA practice (appointments within 30 days) and may result in an overly favorable estimate of teledermatology. Pak et al.,74 based on a DoD population, reported cost savings of $32 per patient if lost productivity was considered. Moreno-Ramirez et al.75 reported that teledermatology was cost-effective for patients referred to a skin cancer clinic.

SAF and LI Study: A comparison of SAF and LI teledermatology found store and forward to be less expensive but less efficient clinically than live interactive teledermatology.80 This analysis considered the educational benefit to general practitioners obtained during the live interactive sessions.

LI Studies: Six studies assessed LI versus usual care including two studies conducted in the United States. Studies had marked differences in design and settings. Most indicated that teledermatology either cost less or was cost efficient compared to usual care, particularly if patients had to travel long distances or certain criteria were met for referral volume and costs.

### Concusions

Cost studies were limited by variations in parameters included and perspectives chosen for the analyses. The majority of studies (including both SAF and LI technologies) found teledermatology to be cost effective if certain critical assumptions were met; the most important included patient travel distance, teledermatology volume, and costs of usual care.

## KEY QUESTION 5. What are the key structural and process elements associated with successful implementation of teledermatology and what are the barriers?

(See Table 11)

Table 11 Key Elements for Success and Barriers to Implementation

[underlined: Facilitators for Implementation]
Determine Relative Advantage
Define objectives
Evaluate alternatives to teledermatology
Clarify if relative risk of implementation is manageable
Conduct initial cost analysis and estimate
Assess Compatibility
Involve all parties in the planning and implementation process
Understand organization layout
Obtain buy-in from key players
Research resources available (primary care, specialty care, community)
Design Low Complexity System
Create easy to use system
Provide onsite technology support
Provide support at referring site (technician/consult manager)
Provide support for additional workload at dermatology site
Incorporate teledermatology into usual processes
Minimize patient waiting time
Ensure Trialability
Reconceptualize professional roles/duties and ensure high levels of flexibility
Provide training and feedback for teledermatology technician/consult manager
Analyze business process and refine
Demonstrate Observability
Determine if objectives are met, disseminate findings and evaluate improvement steps
[underlined: Barriers to Implementation]
Administrative:
Lack of initial administrative support
Lack of ongoing support
Clinical:
Insufficient training of primary care and dermatology in use of teledermatology
Single person trained who may not be available
Inertia among potential users (patients, primary care, dermatology)
Increased workload for primary care and dermatology without additional support
Lack of clinical follow-up
System does not fit objectives of the site
Emphasis on technology rather than practical implementation and ongoing support
Patient:
Patient inconvenience
Lack of education of participants (patients and providers)
Patient preference to see “in-person” dermatologist
Technical:
Software problems
Purchase of general teledermatology equipment rather than standard digital camera
Poor photo quality
Lack of standardization

As summarized above, most research in teledermatology has focused on the accuracy and reliability to diagnose and manage skin conditions in a research setting. However, lessons learned from mature, functioning teledermatology systems include “…that the successful implementation of teledermatology as a routine service requires understanding of and paying great attention to the interplay between social and technical aspects of teledermatology.”81 Finch and colleagues conducted a longitudinal qualitative study based on in-depth semi-structured interviews of dermatologists, nurses, administrators, patient advocates, primary care providers and technologists in 12 teledermatology services in the UK and concluded that “the original… vision of how teledermatology would be utilized, as a technological fix for long waiting lists and consultant shortages, failed to be realized.”82

Several publications have described key elements for successful implementation of teledermatology.83,84,85,86,87,88,89 We summarized these recommendations in Table 11. We attempted to categorize success facilitators using the definitions of Greenhalgh et al.3 We categorized implementation barriers according to administrative, clinical, patient and technical factors. We emphasized factors likely to play a role in VA specific settings. Detailed information on equipment, training in photography, and computerized medical record applications are beyond the scope of this review and are available on the World Wide Web.90,91,92 Because store and forward is the method used almost exclusively for dermatology in the VA system (informal survey December, 2009), we focused on this form of teledermatology in this section. Readers interested in lessons learned from live interactive teledermatology programs are referred to Oakley et al.1 The following summary of key elements of facilitators and barriers to implementation are based on a review of the literature and the authors’ experience with teledermatology within the VA.

### Evaluate the Implementation Setting

Prior to implementing a teledermatology program, a thorough evaluation of organizational issues for the specific VA setting is critical. Most Veterans Integrated Service Networks (VISNs) have at least one larger medical center with dermatology services whereas smaller VAMCs and Community Based Outpatient Clinics (CBOCs) usually do not have on-site dermatology services. There are three likely scenarios for implementing teledermatology in a VA setting:

Intrasite Service: Teledermatology services for a site which already has an onsite VA dermatology service. The main purpose of this type of service is usually triaging dermatology consults.

Intersite Service: Teledermatology services for a site which has no onsite VA dermatology services but a VA with a dermatology clinic is within reasonable driving distance.

New Service: Teledermatology services for a site which has no VA dermatology services. In this scenario, dermatology services are usually either provided by community dermatologists (fee basis or contract), by other VA specialties (surgery, ophthalmology, plastics, infectious diseases, etc), or by primary care without specialty support.

### Define Objectives

The objectives for these three VA scenarios may be very different. As described by Pak,83 common objectives of teledermatology programs include: to improve access to dermatology, to optimize dermatology resources, to reduce dermatology costs, and/or to improve quality of health care (including educating primary care physicians). Identifying specific objectives will help determine the type of teledermatology service best suited for the program’s goals. Because new systems require significant effort, it is crucial that key players (dermatologists, primary care providers, and administrators) perceive that the benefits outweigh the effort and commitment to learning a new system. In the framework of Rogers2 this would be considered determining the relative advantage of teledermatology versus existing services.

### Understand Organizational Issues

Understanding how the VISN or specific medical center delivers dermatological care is important. This is consistent with the Greenhalgh et al.3 recommendation that implementation of teledermatology must be compatible with medical center’s existing values, behaviors and past experiences. Lessons learned from teledermatology in the United Kingdom include that teledermatology is “not a quick nor simple fix for long waiting times in dermatology.”82 Revenue models for Intrasite and Intersite situations are relatively simple as the main dermatology service already provides dermatology care. In these situations, the main goal is often to decrease waiting times and eliminate unnecessary visits to the dermatology clinic; physician workload generally remains stable for dermatology but may increase for primary care. For the New Service scenario, workload for both the dermatology hub site and remote primary care site increase. In this situation, fee basis/consultation costs for the remote site generally decrease; if the two sites have different operating budgets, there will need to be some type of transfer of funds to support the extra workload by the dermatology service. It is also important to realize that not all skin conditions are treatable via teledermatology, so some fee basis/consultation by the referring site to community dermatologists will continue in the New Service scenario and therefore, it is unlikely that these costs will be completely eliminated.

### Evaluate and Provide Required Resources

It is important to evaluate the resources (primary care, dermatology, and other specialty resources) at each site. For the Intrasite and Intersite situations, resources are usually a minor concern because any services not available in primary care are usually available in dermatology, which is either on site (Intrasite) or within driving distance (Intersite). There may be some simple resources needed in primary care (e.g., liquid nitrogen for treatment of warts and actinic keratoses) that will enhance management of common skin conditions in primary care without requiring a dermatology visit. If these additional resources are not created, teledermatology will simply function as a triage tool, eliminating only consultations for straightforward benign growths or treatment for simple skin rashes.73 For the New Service scenario and the Intersite scenario, additional manpower will be needed for follow-up of teledermatology recommendations at the referring site. Often this is a primary care physician, physician assistant, or nurse practitioner who serves as a “local dermatology champion,” someone who is willing to perform skin biopsies, microscopic examinations for fungus, bacteria and scabies, and other relatively minor procedures. If this creates extra workload for that individual, it is important that this be recognized, and if needed, adjustments made to their schedule. Because approximately 50% of VA dermatology visits are related to skin neoplasms, it is important to identify surgical specialties at the referring site for excisions of biopsy-proven skin cancers (e.g., ophthalmology, plastics, general surgery, ear/nose/throat). A key component is whether the implementation scenarios developed are of relatively low complexity and easy to understand and use for both the dermatology and the referring primary care services. In an informal survey of VA dermatology service chiefs in December 2009, three sites volunteered information regarding reasons why they discontinued providing teledermatology services which included that teledermatology: was an ineffective use of physician time, resulted in suboptimal images, and that most patients ultimately needed to come to the dermatology clinic (unpublished).

### Conduct Cost Analysis and Assess Alternatives to Teledermatology

One of the most common mistakes in planning teledermatology programs is to focus primarily on the cost of teledermatology equipment. Store and forward teledermatology equipment generally consists of an off-the-shelf, moderate quality digital camera. Personnel, not equipment costs, are the most important costs in a teledermatology program and all alternatives to teledermatology should be explored. In the New Service scenario, the major alternative is outsourcing (fee basis, consultation). Other common options include hiring a part-time dermatologist or a physician extender with dermatology training. Cost comparisons of teledermatology with these alternatives should include evaluation of the number of consults, number of dermatology visits typically required per patient, average cost per consultation, and the types of services typically provided by community dermatologists. For example, if the major services provided by community dermatologists are procedures, teledermatology is unlikely to yield cost savings because these procedures cannot be performed remotely unless a VA provider is hired or trained to perform these procedures.

### Prepare a Business Model

The business model needs to incorporate support at the remote site for both obtaining and uploading photographs and dermatologic-specific medical history and for follow-up of teledermatology recommendations. This “teledermatology technician” is often a nurse practitioner, physician assistant, nurse, or other medical personnel. While one study found that it took an average of 12 minutes for a primary care physician to take pictures, upload the images, and subsequently implement advice,93 for consistency of photo quality and efficiency of physician time, we do not advocate that primary care physicians function as imagers and/ or technicians. Collins and colleagues94 collected data from 36 general practitioners (who were responsible for obtaining photographs and uploading information) participating in a randomized controlled trial of SAF teledermatology in the United Kingdom; 47% stated that they were not satisfied with teledermatology (21% were satisfied and 32% were unsure) and 50% identified increased workload as a key problem. In his review of teledermatology in the military, Pak stated that “teledermatology has not been embraced by primary care providers because it requires additional resources at the referring site (although less total resources for the higher organization). Most clinics were short on personnel and primary care providers did not have time to take photos.”85 Implementation is more likely to succeed if the teledermatology technician is not the referring provider and has flexible duties so that he/she is available to perform teledermatology services when needed so that the patient does not have to return for imaging. Alternatively, patients can be scheduled at a later time into a teledermatology clinic at the remote site for imaging by the teledermatology technician.

A process for follow-up of teledermatology patients is also critical. In some situations, the teledermatology technician also serves as a coordinator, notifying patients of teledermatology recommendations, coordinating medication recommendations, suggested procedures and appropriate follow-up visits. In all three scenarios (Intersite, Intrasite, and New Service), teledermatology involves a shift from a dermatology referral model to a co-managed/consult model and more workload for primary care providers. Unless support for this increased workload is provided, the system is likely to fail.

### Obtain Organizational Support

It is important to obtain support from key opinion leaders at both the referring site and the dermatology site. Medical center leadership, primary care, surgical subspecialties, dermatology, and pharmacy are important. If the referring site does not perceive a need for teledermatology, there will be minimal incentive to allocate space and resources. For the Intersite and New Service scenarios, the remote pharmacy may need to stock additional dermatology-specific medications and create quick pharmacy orders in the VA Computerized Patient Record System (CPRS). “Marketing” teledermatology to both dermatologists and primary care providers also requires creativity. As emphasized above, if workload increases for either or both services, incentives and support are critical for success. Benefits to primary care providers are often greatest in the New Service scenario. Providing education and quick consultative services to rural primary care physicians can be important motivators. Dermatologists and primary care providers must be involved in program planning from the outset to provide insight on the business model and workflow issues. It is also important to incorporate teledermatology into regular clinic procedures. For example, one teledermatology program failed, in part, simply because it took the dermatologist 15 minutes each way to walk to the telemedicine area.86

### Provide Teledermatology Specific Training

The teledermatologist often provides hands on training for the teledermatology technician. Several helpful resources are available on dermatology-specific photography and recommended medical histories for teledermatology.83,90,91,92 It is ideal if the teledermatology technician and local dermatology champion learn basic dermatology terminology, common skin conditions, and criteria for appropriate teledermatology consults. Periodic refresher training should also be included.