# REFERENCES

1 Oakley A, Rademaker M, Duffill M. Teledermatology in the Waikato region of New Zealand. Journal of Telemedicine & Telecare. 2001;7(Suppl 2):59-61. [pmid: 11747661].
2 Rogers EM. Diffusion of innovations. New York. The Free Press. 1995.
3 Greenhalgh T, Robert G, Bate P, Macfarlane F, Kyriakidou O. Diffusion of innovations in health service organizations: a systematic literature review. Malden, MA. Blackwell Publishing Ltd. 2005.
4 Whiting P, Rutjes AWS, Reitsma JB, Bossuyt PMM, Kleijnen J. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Medical Research Methodology. 2003;3:25. (available at http://www.biomedcentral.com/1471-2288/3/25.
5 Warshaw EM, Lederle FA, Grill JP, et al. Accuracy of teledermatology for pigmented neoplasms. Journal of the American Academy of Dermatology. 2009;61:753-765. [pmid: 19679375].
6 Warshaw EM, Lederle FA, Grill JP, et al. Accuracy of teledermatology for nonpigmented neoplasms. Journal of the American Academy of Dermatology. 2009;60(4):579-88. [pmid: 19217689].
7 Edison KE, Ward DS, Dyer JA, et al. Diagnosis, diagnostic confidence, and management concordance in live interactive and store-and-forward teledermatology compared to in-person examination. Telemedicine Journal & E-Health. 2008;14(9):889-95. [pmid: 19035797].
8 Fabbrocini G, Balato A, Rescigno O, et al. Telediagnosis and face-to-face diagnosis reliability for melanocytic and non-melanocytic ‘pink’ lesions. Journal of the European Academy of Dermatology & Venereology. 2008;22(2):229-34. [pmid: 18211418].
9 Di Stefani A, Zalaudek I, Argenziano G, et al. Feasibility of a two-step teledermatologic approach for the management of patients with multiple pigmented skin lesions. Dermatologic Surgery. 2007;33(6):686-92. [pmid: 17550445].
10 Ferrandiz L, Moreno-Ramirez D, Nieto-Garcia A, et al. Teledermatology-based presurgical management for nonmelanoma skin cancer: a pilot study. Dermatologic Surgery. 2007;33(9):1092-8. [pmid: 17760600].
11 Moreno-Ramirez D, Ferrandiz L, Nieto-Garcia A, et al. Store-and-forward teledermatology in skin cancer triage: experience and evaluation of 2009 teleconsultations. Archives of Dermatology. 2007;143(4):479-84. [pmid: 17438180].
12 Bowns IR, Collins K, Walters SJ, et al. Telemedicine in dermatology: a randomised controlled trial. Health Technology Assessment. 2006;10(43):3-25.
13 Bowns IR, Collins K, Walters SJ, et al. Telemedicine in dermatology: a randomised controlled trial. Health Technology Assessment. 2006;10(43):27-33.
14 Moreno-Ramirez D, Ferrandiz L, Galdeano R, et al. Teledermatoscopy as a triage system for pigmented lesions: a pilot study. Clinical & Experimental Dermatology. 2006;31(1):13-8. [pmid: 16309470].
15 Oakley AM, Reeves F, Bennett J, et al. Diagnostic value of written referral and/or images for skin lesions. Journal of Telemedicine & Telecare. 2006;12(3):151-8. [pmid: 16638237].
16 Mahendran R, Goodfield MJ, Sheehan-Dare RA. An evaluation of the role of a store-and-forward teledermatology system in skin cancer diagnosis and management. Clinical & Experimental Dermatology. 2005;30(3):209-14. [pmid: 15807671].
17 Baba M, Seckin D, Kapdagli S. A comparison of teledermatology using store-and-forward methodology alone, and in combination with Web camera videoconferencing. Journal of Telemedicine & Telecare. 2005;11(7):354-60. [pmid: 16238837].
18 Moreno-Ramirez D, Ferrandiz L, Bernal AP, et al. Teledermatology as a filtering system in pigmented lesion clinics. Journal of Telemedicine & Telecare. 2005;11(6):298-303. [pmid: 16168166].
19 Tucker WF, Lewis FM. Digital imaging: a diagnostic screening tool?. International Journal of Dermatology. 2005;44(6):479-81. [pmid: 15941435].
20 Oztas MO, Calikoglu E, Baz K, et al. Reliability of Web-based teledermatology consultations. Journal of Telemedicine & Telecare. 2004;10(1):25-8. [pmid: 15006212].
21 Ferrara G, Argenziano G, Cerroni L, et al. A pilot study of a combined dermoscopic-pathological approach to the telediagnosis of melanocytic skin neoplasms. Journal of Telemedicine & Telecare. 2004;10(1):34-8. [pmid: 15006214].
22 Piccolo D, Soyer HP, Chimenti S, et al. Diagnosis and categorization of acral melanocytic lesions using teledermoscopy. Journal of Telemedicine & Telecare. 2004;10(6):346-50. [pmid: 15603633].
23 Shapiro M, James WD, Kessler R, et al. Comparison of skin biopsy triage decisions in 49 patients with pigmented lesions and skin neoplasms: store-and-forward teledermatology vs face-to-face dermatology. Archives of Dermatology. 2004;140(5):525-8. [pmid: 15148095].
24 Coras B, Glaessl A, Kinateder J, et al. Teledermatoscopy in daily routine--results of the first 100 cases. Current Problems in Dermatology. 2003;32:207-12. [pmid: 12472014].
25 Du Moulin MF, Bullens-Goessens YI, Henquet CJ, et al. The reliability of diagnosis using store-and-forward teledermatology. Journal of Telemedicine & Telecare. 2003;9(5):249-52. [pmid: 14599326].
26 Pak HS, Harden D, Cruess D, et al. Teledermatology: an intraobserver diagnostic correlation study, Part II. Cutis. 2003;71(6):476-80. [pmid: 12839260].
27 Pak HS, Harden D, Cruess D, et al. Teledermatology: an intraobserver diagnostic correlation study, Part I. Cutis. 2003;71(5):399-403. [pmid: 12769408].
28 Rashid E, Ishtiaq O, Gilani S, et al. Comparison of store and forward method of teledermatology with face-to-face consultation. Journal of Ayub Medical College, Abbottabad: JAMC. 2003;15(2):34-6.
29 Oliveira MR, Wen CL, Neto CF, et al. Web site for training nonmedical health-care workers to identify potentially malignant skin lesions and for teledermatology. Telemedicine Journal & E-Health. 2002;8(3):323-32. [pmid: 12419026].
30 Jolliffe VM, Harris DW, Whittaker SJ. Can we safely diagnose pigmented lesions from stored video images? A diagnostic comparison between clinical examination and stored video images of pigmented lesions removed for histology. Clinical & Experimental Dermatology. 2001;26(1):84-7. [pmid: 11260186].
31 Jolliffe VM, Harris DW, Morris R, et al. Can we use video images to triage pigmented lesions?. British Journal of Dermatology. 2001;145(6):904-10. [pmid: 11899143].
32 Lim AC, Egerton IB, See A, et al. Accuracy and reliability of store-and-forward teledermatology: preliminary results from the St George Teledermatology Project. Australasian Journal of Dermatology. 2001;42(4):247-51. [pmid: 11903155].
33 Taylor P, Goldsmith P, Murray K, et al. Evaluating a telemedicine system to assist in the management of dermatology referrals. British Journal of Dermatology. 2001;144(2):328-33. [pmid: 11251567].
34 Barnard CM, Goldyne ME. Evaluation of an asynchronous teleconsultation system for diagnosis of skin cancer and other skin diseases. Telemedicine Journal & E-Health. 2000;6(4):379-84. [pmid: 11242545].
35 Braun RP, Meier M, Pelloni F, et al. Teledermatoscopy in Switzerland: a preliminary evaluation. Journal of the American Academy of Dermatology. 2000;42(5 Pt 1):770-5. [pmid: 10775852].
36 High WA, Houston MS, Calobrisi SD, et al. Assessment of the accuracy of low-cost store-and-forward teledermatology consultation. Journal of the American Academy of Dermatology. 2000;42(5 Pt 1):776-83. [pmid: 10775853].
37 Piccolo D, Smolle J, Argenziano G, et al. Teledermoscopy--results of a multicentre study on 43 pigmented skin lesions. Journal of Telemedicine & Telecare. 2000;6(3):132-7. [pmid: 10912329].
38 Krupinski EA, LeSueur B, Ellsworth L, et al. Diagnostic accuracy and image quality using a digital camera for teledermatology. Telemedicine Journal. 1999;5(3):257-63. [pmid: 10908439].
39 Lewis K, Gilmour E, Harrison PV, et al. Digital teledermatology for skin tumours: a preliminary assessment using a receiver operating characteristics (ROC) analysis. Journal of Telemedicine & Telecare. 1999;5(Suppl 1):S57-8. [pmid: 10534843].
40 Piccolo D, Smolle J, Wolf IH, et al. Face-to-face diagnosis vs telediagnosis of pigmented skin tumors: a teledermoscopic study. Archives of Dermatology. 1999;135(12):1467-71. [pmid: 10606051].
41 Tait CP, Clay CD. Pilot study of store and forward teledermatology services in Perth, Western Australia. Australasian Journal of Dermatology. 1999;40(4):190-3. [pmid: 10570553].
42 Whited JD, Hall RP, Simel DL, et al. Reliability and accuracy of dermatologists’ clinic-based and digital image consultations. Journal of the American Academy of Dermatology. 1999;41(5 Pt 1):693-702. [pmid: 10534630].
43 Whited JD, Mills BJ, Hall RP, et al. A pilot trial of digital imaging in skin cancer. Journal of Telemedicine & Telecare. 1998;4(2):108-12. [pmid: 9744167].
44 Kvedar JC, Edwards RA, Menn ER, et al. The substitution of digital images for dermatologic physical examination. Archives of Dermatology. 1997;133(2):161-7. [pmid: 9041828].
45 Lyon CC, Harrison PV. A portable digital imaging system in dermatology: diagnostic and educational applications. Journal of Telemedicine & Telecare. 1997;3(Suppl 1):81-3. [pmid: 9218395].
46 Zelickson BD, Homan L. Teledermatology in the nursing home. Archives of Dermatology. 1997;133(2):171-4. [pmid: 9041829].
47 Nordal EJ, Moseng D, Kvammen B, et al. A comparative study of teleconsultations versus face-to-face consultations. Journal of Telemedicine & Telecare. 2001;7(5):257-65. [pmid: 11571079].
48 Gilmour E, Campbell SM, Loane MA, et al. Comparison of teleconsultations and face-to-face consultations: preliminary results of a United Kingdom multicentre teledermatology study. British Journal of Dermatology. 1998;139(1):81-7. [pmid: 9764153].
49 Lesher JL Jr, Davis LS, Gourdin FW, et al. Telemedicine evaluation of cutaneous diseases: a blinded comparative study. Journal of the American Academy of Dermatology. 1998;38(1):27-31. [pmid: 9448201].
50 Loane MA, Corbett R, Bloomer SE, et al. Diagnostic accuracy and clinical management by realtime teledermatology. Results from the Northern Ireland arms of the UK Multi-centre Teledermatology Trial. Journal of Telemedicine & Telecare. 1998;4(2):95-100. [pmid: 9744165].
51 Lowitt MH, Kessler II, Kauffman CL, et al. Teledermatology and in-person examinations: a comparison of patient and physician perceptions and diagnostic agreement. Archives of Dermatology. 1998;134(4):471-6. [pmid: 9554300].
52 Phillips CM, Burke WA, Allen MH, et al. Reliability of telemedicine in evaluating skin tumors. Telemedicine Journal. 1998;4(1):5-9. [pmid: 9599075].
53 Oakley AM, Astwood DR, Loane M, et al. Diagnostic accuracy of teledermatology: results of a preliminary study in New Zealand. New Zealand Medical Journal. 1997;110(1038):51-3. [pmid: 9076285].
54 Phillips CM, Burke WA, Shechter A, et al. Reliability of dermatology teleconsultations with the use of teleconferencing technology. Journal of the American Academy of Dermatology. 1997;37(3 Pt 1):398-402. [pmid: 9308553].
55 Warshaw EM, Gravely AA, Nelson DB. Accuracy of Teledermatology/Teledermatoscopy and Clinical-Based Dermatology for Specific Categories of Skin Neoplasms. Submitted to Journal of the American Academy of Dermatology (JAAD) on 9-9-09 JAAD-D-09-0124, resubmitted 10-9-09, accepted 10-30-09.
56 Loane MA, Gore HE, Bloomer SE, et al. Preliminary results from the Northern Ireland arms of the UK Multicentre Teledermatology Trial: is clinical management by realtime teledermatology possible?. Journal of Telemedicine & Telecare. 1998;4(Suppl 1):3-5. [pmid: 9640716].
57 Eminovic N, de Keizer NF, Wyatt JC, et al. Teledermatologic consultation and reduction in referrals to dermatologists: a cluster randomized controlled trial. Archives of Dermatology. 2009;145(5):558-64. [pmid: 19451500].
58 Pak H, Triplett CA, Lindquist JH, et al. Store-and-forward teledermatology results in similar clinical outcomes to conventional clinic-based care. Journal of Telemedicine & Telecare. 2007;13(1):26-30. [pmid: 17288655].
59 Granlund H, Thoden CJ, Carlson C, et al. Realtime teleconsultations versus face-to-face consultations in dermatology: immediate and six-month outcome. Journal of Telemedicine & Telecare. 2003;9(4):204-9. [pmid: 12952690].
60 Whited JD, Hall RP, Foy ME, et al. Patient and clinician satisfaction with a store-and-forward teledermatology consult system. Telemedicine Journal & E-Health. 2004;10(4):422-31. [pmid: 15689645].
61 Weinstock MA, Nguyen FQ, Risica PM. Patient and referring provider satisfaction with teledermatology. Journal of the American Academy of Dermatology. 2002;47(1):68-72. [pmid: 12077584].
62 Williams TL, Esmail A, May CR, et al. Patient satisfaction with teledermatology is related to perceived quality of life. British Journal of Dermatology. 2001;145(6):911-7. [pmid: 11899144].
63 Williams TL, Esmail A, May CR, et al. Patient satisfaction with store-and-forward teledermatology. Journal of Telemedicine & Telecare. 2001;7(Suppl 1):45-6. [pmid: 11576488].
64 Pak HS, Welch M, Poropatich R. Web-based teledermatology consult system: preliminary results from the first 100 cases. Studies in Health Technology & Informatics. 1999;64:179-84. [pmid: 10747537].
65 Hicks LL, Boles KE, Hudson S, et al. Patient satisfaction with teledermatology services. Journal of Telemedicine & Telecare. 2003;9(1):42-5. [pmid: 12641892].
66 Lamminen H, Tuomi ML, Lamminen J, et al. A feasibility study of realtime teledermatology in Finland. Journal of Telemedicine & Telecare. 2000;6(2):102-7. [pmid: 10824378].
67 Loane MA, Bloomer SE, Corbett R, et al. Patient satisfaction with realtime teledermatology in Northern Ireland. Journal of Telemedicine & Telecare. 1998;4(1):36-40. [pmid: 9640708].
68 Hsiao JL, Oh DH. The impact of store-and-forward teledermatology on skin cancer diagnosis and treatment. Journal of the American Academy of Dermatology. 2008;59(2):260-7. [pmid: 18485526].
69 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemedicine Journal & E-Health. 2002;8(3):313-21. [pmid: 12419025].
70 Loane MA, Bloomer SE, Corbett R, et al. A randomized controlled trial assessing the health economics of realtime teledermatology compared with conventional care: an urban versus rural perspective. Journal of Telemedicine & Telecare. 2001;7(2):108-18. [pmid: 11331049].
71 Wootton R, Bloomer SE, Corbett R, et al. Multicentre randomised control trial comparing real time teledermatology with conventional outpatient dermatological care: societal cost-benefit analysis. BMJ. 2000;320(7244):1252-6. [pmid: 10797038].
72 Knol A, van den Akker TW, Damstra RJ, et al. Teledermatology reduces the number of patient referrals to a dermatologist. Journal of Telemedicine & Telecare. 2006;12(2):75-8. [pmid: 16539753].
73 Whited JD, Datta S, Hall RP, et al. An economic analysis of a store and forward teledermatology consult system. Telemedicine Journal & E-Health. 2003;9(4):351-60. [pmid: 14980092].
74 Pak HS, Datta SK, Triplett CA, et al. Cost minimization analysis of a store-and-forward teledermatology consult system. Telemedicine Journal & E-Health. 2009;15(2):160-5. [pmid: 19292625].
75 Moreno-Ramirez D, Ferrandiz L, Ruiz-de-Casas A, et al. Economic evaluation of a store-and-forward teledermatology system for skin cancer patients. Journal of Telemedicine & Telecare. 2009;15(1):40-5. [pmid: 19139219].
76 Burgiss SG, Julius CE, Watson HW, et al. Telemedicine for dermatology care in rural patients. Telemedicine Journal. 1997;3(3):227-33. [pmid: 10174347].
77 Loane MA, Oakley A, Rademaker M, et al. A cost-minimization analysis of the societal costs of realtime teledermatology compared with conventional care: results from a randomized controlled trial in New Zealand. Journal of Telemedicine & Telecare. 2001;7(4):233-8. [pmid: 11506759].
78 Bergmo TS. A cost-minimization analysis of a realtime teledermatology service in northern Norway. Journal of Telemedicine & Telecare. 2000;6(5):273-7. [pmid: 11070588].
79 Armstrong AW, Dorer DJ, Lugn NE, et al. Economic evaluation of interactive teledermatology compared with conventional care. Telemedicine Journal & E-Health. 2007;13(2):91-9. [pmid: 17489695].
80 Loane MA, Bloomer SE, Corbett R, et al. A comparison of real-time and store-and-forward teledermatology: a cost-benefit study. British Journal of Dermatology. 2000;143(6):1241-7. [pmid: 11122028].
81 English JS, Eedy DJ. Has teledermatology in the U.K. finally failed?. British Journal of Dermatology. 2007;156(3):411. [pmid: 17300226].
82 Finch TL, Mair FS, May CR. Teledermatology in the UK: lessons in service innovation. British Journal of Dermatology. 2007;156(3):521-7. [pmid: 17300243].
83 Pak HS. Implementing a teledermatology programme. Journal of Telemedicine & Tele-care. 2005;11(6):285-93.
84 Stronge AJ, Nichols T, Rogers WA, et al. Systematic human factors evaluation of a teledermatology system within the U.S. military. Telemedicine Journal & E-Health. 2008;14(1):25-34. [pmid: 18328022].
85 Pak HS. Teledermatology and teledermatopathology. Seminars in Cutaneous Medicine & Surgery. 2002;21(3):179-89. [pmid: 12322991].
86 Carlos ME, Pangelinan SI. Teledermatology in Department of Defense Health Services Region 10. Journal of Healthcare Information Management. 1999;13(4):59-69. [pmid: 10747703].
87 Finch T. Teledermatology for chronic disease management: coherence and normalization. Chronic Illness. 2008;4(2):127-34. [pmid: 18583450].
88 Pak H. Teledermatology in North America. Current Problems in Dermatology. 2003;32:222-5. [pmid: 12472016].
89 See A, Lim AC, Le K, et al. Operational teledermatology in Broken Hill, rural Australia. Australasian Journal of Dermatology. 2005;46(3):144-9. [pmid: 16008643].
90 Krupinski E, Burdick A, Pak Hon, et al. Practice Guidelines for Teledermatology, December 2007. Available at: http://www.americantelemed.org/files/public/standards/Tele-derm_guidelines_v10final_withCOVER.pdf. Accessed November, 2009.
91 Vidmar DA. The Idiot’s Guide to Teledermatology Imaging. Available at: www.healthcare.hqusareur.army.mil/Telemedicine2004.02.04/Pubs/Telederm.pdf. Accessed November, 2009.
92 VHA Telehealth Operations Manual for Teledermatology. Revision July 30, 2008;. Available at: http://vaww.carecoordination.va.gov/store-forward/teledermatology/. Accesssed November, 2009.
93 van den Akker TW, Reker CH, Knol A, et al. Teledermatology as a tool for communication between general practitioners and dermatologists. Journal of Telemedicine & Tele-care. 2001;7(4):193-8.
94 Collins K, Bowns I, Walters S. General practitioners’ perceptions of asynchronous telemedicine in a randomized controlled trial of teledermatology. Journal of Telemedicine & Telecare. 2004;10(2):94-98. [pmid: 15068645].
95 Hersh WR, Hickam DH, Severance SM, Dana TL, Krages KP, Helfand M. Telemedicine for the Medicare Population: Update. Evidence Report/Technology Assessment No. 131 (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024.). AHRQ Publication No. 06-E007. Rockville, MD. Agency for Healthcare Research and Quality. February. 2006.