# METHODS

## TOPIC DEVELOPMENT, TECHNICAL EXPERT PANEL

This topic was nominated by the Center for Chronic Disease Outcomes Research, Minneapolis VA Medical Center in consultation with the VA Evidence Synthesis Program. Robert Dellavalle, MD, PhD; Dennis Oh, MD; and John Whited, MD, MHS agreed to serve on the Technical Expert Panel (TEP) for the project. The TEP and the VA Department of Health Services Research and Development (HSR&D) collaborated with the Minneapolis VA Evidence Synthesis Program (ESP) to identify and refine key questions including populations, interventions, comparisons, outcomes, and settings of relevance.

## SEARCH STRATEGY

We searched MEDLINE (OVID) and PubMed for clinical trials, systematic reviews, cost studies, and implementation papers from 1990 to June, 2009 using standard search terms. We chose 1990 as the start date for the search based on consensus from the TEP members that studies prior to 1990 would likely not be relevant to current practice. We limited the search to articles involving human subjects and published in English language. Search terms included: remote consult/consultation, electronic mail, telecommunications, telemedicine, telepathology, dermatology, and teledermatology. (Appendix A)

### STUDY SELECTION

Titles and abstracts identified from the search were reviewed by physicians and research associates trained in the critical analysis of literature to identify peer-reviewed articles likely related to one or more of the key questions.

Specific inclusion criteria were as follows:

1. Controlled trial (questions 1 and 2)
2. Store and forward (SAF) or live interactive (LI) teledermatology

Specific exclusion criteria included:

1. Teledermatology involving mobile phones
2. Non-teledermatology settings (e.g., imaging analyses, telemedicine studies other than teledermatology, videomicroscopy studies, basic science, imaging techniques)
3. Dermatopathology studies
4. Reviews, teledermatology program descriptions, and history of teledermatology (unless relevant to questions 3, 4 or 5)
5. Studies of computer-aided diagnoses only (e.g., pigmented lesions)
6. Survey studies addressing outcomes other than those defined in questions 1–5
7. Teledermatology as an educational tool for primary care physicians or residents
8. Technology assessment only
9. Remote monitoring of known diagnoses (e.g., leg ulcers, post-operative wounds)
10. Teledermatology involving patient generated photos and/or history (without a referring provider)
11. Non-English language
12. Case series with no control group (questions 1 and 2 only)
13. Commentaries, editorials or meeting abstracts (unless relevant to question 5)
14. Studies involving one diagnosis only (e.g., leprosy) or only acne and warts; studies of one category of skin conditions (e.g., pigmented lesions which could have multiple diagnoses) were included
15. Duplicate publications; if both preliminary and final reports were published, the final data analysis was utilized
16. Pediatric population only (as this would not be relevant to VA population); studies involving both adults and children were included.

For key questions 1 and 2 we included clinical trials of teledermatology with an in-person dermatology control group if they provided information related to diagnostic and management accuracy or concordance. For key question 3, we extracted data related to patient satisfaction and preferences. For key question 4 we obtained articles and evaluated past reviews assessing cost analyses of teledermatology programs with an emphasis on studies applicable to practice in the United States. For key question 5 we conducted a narrative review of identifiable information related to structural and process elements associated with successful implementation of teledermatology as well as barriers to implementation framing the section around the conceptual model developed by Greenhalgh et al.3

## DATA ABSTRACTION

Two research associates (YH, NG) extracted data on study design, patient characteristics, lesion type(s), intervention(s), comparison(s), and outcome(s) from each included study for questions 1 to 4 (Appendix B – Data Extraction Form). The principal investigator verified all extracted data for these outcomes and also summarized data on implementation issues (question 5). Our main outcomes were diagnostic and management accuracy and concordance as defined in Table 1.

Table 1 Definitions of Outcomes

Outcome (Statistics Reported) | Definition
ACCURACY | Match of TD (teledermatology) or CD (clinical dermatology) with Gold Standard of Histopathology or other Laboratory Test
Diagnostic Accuracy – CD (% Correct, Kappa statistic, Sensitivity/Specificity) | Match of the CD diagnosis and histopathology/other lab test [underlined: Aggregated:] Match of any of the CD diagnoses (primary or differential diagnoses) with histopathology/lab diagnosis [underlined: Primary:] Match of the primary CD diagnosis with histopathology/lab diagnosis
Diagnostic Accuracy – TD (% Correct, Kappa statistic, Sensitivity/Specificity) | Match of the TD diagnosis and histopathology/other lab test [underlined: Aggregated:] Match of any of the TD diagnoses (primary or differential diagnoses) with histopathology/lab diagnosis [underlined: Primary:] Match of the primary TD diagnosis with histopathology/lab diagnosis
Management Accuracy – CD (% Correct) | Match of the CD management plan with management based on histopathology/other lab test
Management Accuracy – TD (% Correct) | Match of the TD management plan with management based on histopathology/other lab test
CONCORDANCE | Agreement between TD and CD
Diagnostic Concordance (% Agreement, Kappa statistic) | Agreement between the TD diagnosis and the CD diagnosis [underlined: Aggregated:] Agreement of any of the TD diagnoses (primary or differential diagnoses) with any of the CD diagnoses (primary or differential diagnoses) [underlined: Primary:] Agreement of the primary TD diagnosis with the primary CD diagnosis
Management Concordance (% Agreement, Kappa statistic) | Agreement between the TD management and the CD management

## QUALITY ASSESSMENT

We used the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) instrument to assess for study quality for studies pertaining to key questions 1 and 2.^4^ QUADAS is the first standardized, systematically developed, Delphi derived instrument used to assess methodological quality of studies of diagnostic tests. The QUADAS tool includes 14 questions that assess potential outcome bias. Items are scored as “yes,” “no,” or “uncertain” and can be grouped under 4 main domains: subject selection, index test, reference test, and data analysis. A summary score is not a recommended final metric of quality though we arbitrarily reported on the number of studies scored with a “yes” on at least 10 of 14 items as well the individual “yes” scores for each of the 4 domains. We believe such reporting can assist the reader in determining potential sources of study bias and encourage future researchers to adhere to these quality measures. Two extractors (EW, YH) independently reviewed all studies for quality. A third investigator (TW) resolved scoring discrepancies through review and discussion.

## DATA SYNTHESIS

We reported results from each study separately for each outcome and method of outcome reporting (e.g., percent correct, kappa statistic, sensitivity/specificity, and concordance). Results were stratified according to whether the intervention was SAF or LI. We evaluated studies according to sample size, type of dermatological conditions studied, and whether they enrolled users of, and assessed outcomes in, the VA health care system. Due to considerable heterogeneity in study design, patient and lesion characteristics, and outcome reporting methods results were rarely pooled and instead displayed graphically according to teledermatology technology and sample size. If appropriate, weighted mean differences based on study sample sizes were calculated for the percentage of correct diagnoses for TD and usual care. Most pooled estimates were only possible using data from a subsample of eligible studies; caution is recommended in interpreting these pooled findings.

## PEER REVIEW

A draft report was sent to TEP members and peer reviewers identified by VA HSR&D. Reviewer comments and author responses are summarized in Appendix C.