# INTRODUCTION AND BACKGROUND

Telemedicine uses telecommunication technology to transfer medical information. Due to the visual nature of a skin examination, telemedicine, specifically, teledermatology, is a potentially valuable tool in the diagnosis and management of dermatologic diseases for patients in rural areas (including rural Veterans Affairs Medical Centers [VAMCs] and Community Based Outpatient Clinics [CBOCs]) where a dermatologist may not be available. Teledermatology may also be useful in primary care settings to triage cases and limit unnecessary dermatology clinic referrals as well as to assist with follow-up care or monitoring after an in-person dermatology visit. Two particular types of teledermatology are commonly employed. Store and forward (SAF) uses asynchronous still digital image technology for communication, similar to an email system. Participants are typically separated by both time and space. Real-time or live interactive (LI) uses video-conferencing technology. Participants are separated by space, not by time. Both systems have advantages and disadvantages. SAF requires less technological sophistication and lower cost equipment than LI, permits the referring provider to submit the consultation with accompanying image(s) to the dermatologist for review at a later time, and does not require the dermatologist to be immediately available or on-call to urgently review the teleconsult while the patient is in the primary care clinic. In contrast, LI permits a more dynamic assessment of the skin condition and allows the dermatologist to obtain a real-time history from both the patient and the referring provider, to make an immediate initial diagnosis, and to provide a management plan. Owing partly to the technological simplicity of SAF and the fact that SAF allows the dermatologist to review the telemedicine consult either outside of normal clinic hours or bundled into separate time slots within an existing clinic, SAF is the more widely used form of teledermatology in the VA. An informal, unpublished survey of VA dermatology chiefs in December 2009 found that 44% (19/43) of responding VA dermatology services are utilizing teledermatology; 17 VAs are using SAF, one is using LI, and one is using both methodologies.

The diagnostic and management accuracy (match of teledermatology diagnosis or in-person dermatology diagnosis with a gold standard of histopathology or other laboratory test) and concordance (agreement between teledermatology and in-person dermatology) of these technologies, their cost-effectiveness, and their impact on clinical management and patient outcomes (including satisfaction) are not well understood. Although research demonstrating that teledermatology is accurate and cost-effective is essential, it is not sufficient. Lessons learned from mature, functioning teledermatology systems in the United Kingdom and New Zealand include that “initial concerns about the ability to diagnose and manage patients by telemedicine have turned out to be less important that the practical issues of implementation.”1 Incorporating research findings into clinical practice requires identifying and removing structural and process barriers as well as enhancing critical components to success. Based on the work of Rogers2 and a systematic review of empirical research studies, Greenhalgh et al. developed a conceptual model for considering the determinants of diffusion, dissemination, and implementation of innovations in health service delivery and organization.3 Greenhalgh et al. concluded that adoption of any health care technology increases to the degree that such technology is perceived as possessing the following qualities in relation to existing practice: relative advantage (the new technology is better than current processes); compatibility (consistency with existing values, behaviors and past experiences); low complexity (easy to understand and use); trialability (can be modified and experimented with on a limited basis), and observability (results of the change are visible).3

We conducted an evidence synthesis report to systematically review and summarize the scientific literature addressing: 1) teledermatology for the diagnosis of skin conditions, 2) teledermatology for the management of skin conditions, 3) clinical outcomes when teledermatology is used, 4) the cost of teledermatology compared with usual care (in-person dermatology), and 5) key elements of and barriers to successful implementation of teledermatology. We addressed the following key questions:

- 1a. How does the accuracy of teledermatology compare to usual care (in-person dermatology) for the diagnosis of skin conditions?
- 1b. How does the concordance of teledermatology compare to usual care (in-person dermatology) for the diagnosis of skin conditions?
- 2a. How does the accuracy of teledermatology compare to usual care (in-person dermatology) for clinical management of skin conditions?
- 2b. How does the concordance of teledermatology compare to usual care (in-person dermatology) for clinical management of skin conditions?
- 3. How do clinical outcomes (clinical course, satisfaction, quality of life, visits avoided) of teledermatology compare to usual care (in-person dermatology) for skin conditions?
- 4. How does the cost of teledermatology compare to usual care (in-person dermatology)?
- 5. What are the key structural and process elements associated with successful implementation of teledermatology and what are the barriers?