# EVIDENCE TABLE: OVERVIEW OF STUDIES FOR KEY QUESTIONS 1 AND 2

Diagnostic Accuracy, Diagnostic Concordance, Management Accuracy, Management Concordance

Study Country Study design Funding | # Subjects # Conditions | Population and Study Characteristics | Teledermatology Characteristics | Outcomes Evaluated | Quality Rating
A. Store and forward systems studies (n=41)
Warshaw 2009^5^ United States, US armed service personnel/veterans Repeated Measure Funding: Department of Veterans Affairs Health Services R&D Service | 542 542 | Mean age (range): 66 years (23–94) Gender: female 4%, male 96% Race/ethnicity: white 97% Condition characteristics: Benign Neoplasm:267 Keratinocyte Carcinoma:84 Dysplastic Nevus: 155 Melanoma:36 Inclusion criteria: PSL Exclusion criteria: Skin tags, previously biopsied lesions Study duration (months): 3 | Nikon Coolpix 4500, 3Gen Dermlite, Minolta X370 with Heine dermphot (TDSC) Photographer: Support staff Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: Yes Management Concordance: No | Overall QUADAS score: 12/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 1/2
Warshaw 2009^6^ United States, US armed service personnel/veterans Repeated Measure Funding: Department of Veterans Affairs Health Services R&D Service | 728 728 | Mean age (range): 71 years (21–94) Gender: female 2%, male 98% Race/ethnicity: white 99% Condition Characteristics: Keratinocyte Carcinoma - 385 Actinic Keratosis - 81 Benign Neoplasm - 258 Other - 4 Inclusion criteria: Non-pigmented neoplasms Exclusion criteria: Skin tags, previously biopsied lesions Study duration (months): 34 | Nikon Coolpix 4500 3Gen Dermlite (TDSC) Photographer: Support staff Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: Yes Management Concordance: No | Overall QUADAS score: 12/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 1/2
Edison 2008^7^ United States Repeated Measure Both SAF and LI Funding: Federal Office for the Advancement of Telehealth, Health Resources and Services Administration | 110 110 | Mean age (range): 42 (7–92) Gender: female 69%, male 31% Race/ethnicity: white 85%, black 12%, Asian 2%, Hispanic 1% Condition Characteristics (Only reported for 70): Actinic Keratosis - 10 Acneiform - 12 Benign Neoplasm - 19 Dysplastic nevus - 1 Infectious - 7 Eczematous - 8 Other – 13 Inclusion criteria: New pts on study days Exclusion criteria: NR Study duration (months): 18 | Camera: NR Photographer: NR Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Fabbrocini 2008^8^ Italy Repeated Measure Funding: NR | NR 44 | Age: NR Gender: NR Race/Ethnicity: NR Condition characteristics: Melanoma - 22 Benign Neoplasm - 15 Dysplastic nevi - 7 Inclusion criteria: Non-pigmented, absence of regular network, or diameter <5 mm Exclusion criteria: NR Study duration (months): NR | Nikon 4500 Coolpix, Wild M650 Steromicroscope Photographer: Dermatologist Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: No | Overall QUADAS score: 8/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 1/3 Data analysis: 1/2
Di Stefani 2007^9^ Italy Repeated Measure Funding: NR | 18 465 | Mean age (range): 28.4 years (10–55) Gender: female 39%, male 61% Race/ethnicity: NR Condition characteristics: PSL Inclusion criteria: ≥3 clinically atypical nevi on back Exclusion criteria: NR | Nikon 990 (macro), Videocap digital videodermoscopy Photographer: NR Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: No Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Ferrandiz 2007^10^ Spain Repeated Measure Funding: Instituto Carlos III | 134 134 | Mean age: 70.3 years Gender: female 39%, male 61% Race/ethnicity: NR Condition characteristics: Keratinocyte Carcinoma - 95 Actinic keratosis - 14 Melanoma - 1 Other - 3 Benign Neoplasm - 17 Inclusion criteria: Non-melanoma skin cancer or fast-growing vascular tumor Exclusion criteria: “Lesions expected to require major reconstruction”, melanoma Study duration (months): 12 | Nikon Coolpix 4300 Photographer: NR Time between photograph and gold standard (days): mean 26 days | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 6/7 Reference test: 3/3 Data analysis: 0/2
Moreno-Ramirez11 2007 Spain Repeated Measure Funding: Instituto Carlos III | 882 890 | Mean age: 41.5 years Gender: female 59%, male 41% Race/ethnicity: NR Condition characteristics: Benign Neoplasm - 548 Keratinocyte Carcinoma - 119 Actinic keratosis - 102 Melanoma - 18 Infectious - 9 Papulosquamous/Other - 15 Other Malignant Neoplasm - 3 Dysplastic nevus - 76 Inclusion criteria: Circumscribed lesions Exclusion criteria: NR Study duration (months): 15 | Nikon Coolpix 4300 Photographer: NR Time between photograph and gold standard (days): <31 76 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 12/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 6/7 Reference test: 3/3 Data analysis: 2/2
Bowns 2006^12^ United Kingdom Randomized controlled trial; Data extracted from TD arm Funding: National Health Service R&D grant | 92 92 | Mean age: intervention 43.6 years, Gender: female 63%, male 37% Race/ethnicity: NR Condition characteristics: Malignancy- 3 Benign Neoplasm –5 Infectious - 4 Eczematous – 11 Papulosquamous/Other - 62 Acneiform - 7 Inclusion criteria: ≥ 16 years old, had not seen dermatologist in last year Exclusion criteria: genital lesions Study duration (months): NR | Nikon Coolpix 900 Photographer: Primary care staff, often general practitioner Time between photograph and gold standard (days): mean 60 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 2/2 Index test: 4/7 Reference test: 2/3 Data analysis: 2/2
Bowns 2006^13^ United Kingdom Repeated Measure Funding: National Health Service R&D grant | 256 256 | Mean age: NR Gender: female 53%, male 47% Race/ethnicity: NR Condition characteristics: Keratinocyte Carcinoma – 54 Actinic keratosis-15 Dysplastic nevus-3 Melanoma-24 Benign neoplasm-159 Other-1 Inclusion criteria: Suspected skin cancer Exclusion criteria: NR Study duration (months): NR | Camera: NR Photographer: Medical Photography Department Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 6/7 Reference test: 3/3 Data analysis: 2/2
Moreno-Ramirez 2006^14^ Spain Repeated Measure Funding: Instituto Carlos III | 61 61 | Mean age (range): 39 years (1–73) Gender: female 71%, male 29%, Race/ethnicity: NR Condition characteristics: Keratinocyte Carcinoma - 2 Benign Neoplasm - 54 Melanoma - 1 Dysplastic Nevus - 1 Inclusion criteria: PSL Exclusion criteria: Pts who did not show to CD Study duration (months): 2 | Nikon Coolpix 4500 DermLite (TDSC) Photographer: General practitioner Time between photograph and gold standard (days): <30 | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: No | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 6/7 Reference test: 3/3 Data analysis: 1/2
Oakley 2006^15^ New Zealand Repeated Measure Funding: NR | 73 109 | Mean age (range): 59 years (16–93) Gender: female 64%, male 36% Race/ethnicity: NR Condition characteristics: Keratinocyte Carcinoma - 43 Actinic keratoses - 17 Melanoma - 8 Benign neoplasms - 37 Papulosquamous/Other - 4 Inclusion criteria: New pts with skin growth Exclusion criteria: Inflammatory dermatoses, infections, resolved lesions, poor quality images Study duration (months): NR | Nikon Coolpix 955 38 TD (6 were trainee dermatologists) Photographer: medical student Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Baba 2005^17^ Turkey Repeated Measure Both SAF and LI Funding: NR | 228 242 | Mean age (range): 35 years (2–82) Gender: female 63%, male 37% Race/ethnicity: NR Condition characteristics: Acneiform - 41 Infectious - 54 Pre-malignant/Malignant- 2 Eczematous - 46 Benign Neoplasms - 45 Papulosquamous/Other - 54 Inclusion criteria: New dermatology pts Exclusion criteria: None Study duration (months): 2.3 | Canon Powershot S10 Two dermatologists with 3 to 5 years experience. Photographer: Nurse Time between photographing and gold standard test (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 6/7 Reference test: 2/3 Data analysis: 0/2
Mahendran 2005^16^ United Kingdom Repeated Measure Funding: NR | 163 163 | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: Benign Neoplasm - 81 Keratinocyte Carcinoma - 48 Actinic keratoses - 10 Melanoma - 5 Infectious - 3 Papulosquamous/Other - 10 Dysplastic nevus - 6 Inclusion criteria: Pts with suspected skin cancer, informed consent Exclusion criteria: Pts who did show to CD (number NR) Study duration (months): 18 | Nikon Coolpix 950 2 different dermatologists and a 3rd year trainee dermatologist viewed all the cases as well Photographer: General practitioner Time between photograph and gold standard (days): <14 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 8/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 5/7 Reference test: 2/3 Data analysis: 1/2
Moreno-Ramirez 2005^18^ Spain Repeated Measure Funding: Grant from Instituto Carlos III | 108 108 | Mean age (range): 43 years (2 to 84 Gender: female 65%, male 35% Race/ethnicity: NR Condition characteristics (for 57 biopsied PSL): Keratinocyte Carcinoma - 23 Benign Neoplasm - 12 Dysplastic Nevi -16 Melanoma - 6 Inclusion criteria: changing, new, symptomatic or concerning pigmented lesions Exclusion criteria: NR Study duration (months): 3 | Nikon Coolpix 4300 Photographer: General practitioner Time between photograph and gold standard (days): mean 8 days (range 5–14) | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 2/3 Data analysis: 0/2
Tucker 2005^19^ United Kingdom Repeated Measure Funding: NR | 75 84 | Mean age: NR Gender: female 64%, male 36% Race/ethnicity: NR Condition characteristics: NR Inclusion criteria: NR Exclusion criteria: NR Study duration (months): 1 | Fujifilm MX-1700 Photographer: dermatologists Time between photograph and gold standard (days): 0 | Diagnostic Accuracy : No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 2/2
Ferrara 2004^21^ Italy Repeated Measure Funding: NR | 12 12 | Median age (range): 41 years (14–71) Gender: female 17%, male 83% Race/ethnicity: NR Condition characteristics: PSL Benign Neoplasm - 5 Melanoma - 7 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): NR | TDSC: Heine Dermaphot Molemax Videocap Photographer: NR Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: No | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 6/7 Reference test: 3/3 Data analysis: 0/2
Oztas 2004^20^ Turkey Repeated Measure Funding: NR | 125 125 | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: Infectious - 50 Tumors (not further defined) -12 Eczematous - 10 Acneiform - 8 Papulosquamous/Other - 39 Benign Neoplasm - 6 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): NR | Canon Powershot 70 Photographer: NR Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Piccolo 2004^22^ Italy Repeated Measure Funding: NR | 73 77 | Mean age (range): 28 years (4–77) Gender: female 53%, male 47% Race/ethnicity: NR Condition characteristics: Acral PSL Benign - 71 Melanomas - 6 Inclusion criteria: Acral melanocytic lesions Exclusion criteria: NR Study duration (months): NR | TDSC: Molemax II, Heine Dermaphot Photographer: NR Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: No | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 2/3 Data analysis: 0/2
Shapiro 2004^23^ United States Repeated Measure Funding: University of Pennsylvania Department of Dermatology | 49 49 | Mean age: NR Gender: female 46%, male 54% Race/ethnicity: NR Condition characteristics: Skin growths Inclusion criteria: Skin growth referred by general practitioner Exclusion criteria: Previous dermatology evaluation Study duration (months): NR | Olympus D-600L Photographer: General practitioner Time between photograph and gold standard (days): <16 | Diagnostic Accuracy: No Diagnostic Concordance: No Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 2/2
Coras 2003^24^ Germany Repeated Measure Funding: NR | NR 45 | Age, gender, and race/ethnicity: NR Condition characteristics: PSL Benign Neoplasm - 24 Dysplastic Nevus - 5 Melanoma - 16 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): 16 | Dermogenius ultra Photographer: Clinic dermatoscopic examiner Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: No | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 1/2
Du Moulin 2003^25^ Netherlands Repeated Measure Funding: University Hospital Maastricht and Ministry of Economic Affairs | 106 106 | Mean age: 47 years Gender: NR Race/ethnicity: NR Condition characteristics: Malignant/Premalignant - 6 Benign Neoplasms - 12 Eczematous 28 Infectious- 15 Acneiform - 13 Papulosquamous/Other - 22 Inclusion criteria: Pts referred from general practitioner Exclusion criteria: Dermatologic referral clearly indicated Study Duration (months): 11 | Ricoh 5000 Photographer: General practitioner Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 12/14 Sources of bias identified by QUADAS Selection: 2/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Pak 2003 (Part I27 and Part II26) United States, 100% army veterans, or relatives Repeated Measure Funding: Walter Reed Army Medical Center | 404 404 | Mean age (range): 59 years (18–92) Gender: female 43%, male 57% Race/ethnicity: white 82%, black 13%, Asian/Hispanic 5% Condition characteristics: Infectious - 31 Premalignant/Malignant - 54 Acneiform - 28 Benign neoplasm - 115 Eczematous - 44 Papulosquamous/Other - 132 Inclusion criteria: Adult new pts Exclusion criteria: Medical emergencies Study duration (months): 4 | Olympus D-600L Nikon Coolpix 900 Photographer: Nurse Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 2/2 Index test: 6/7 Reference test: 2/3 Data analysis: 0/2
Rashid 2003^28^ Pakistan Repeated Measure Funding: NR | 33 33 | Age, gender, and race/ethnicity: NR Condition characteristics: Keratinocyte Carcinoma - 1 Infectious - 9 Eczematous - 4 Benign Neoplasm - 3 Papulosquamous/Other - 16 Inclusion criteria: NR Exclusion criteria: Common conditions such as acne and melasma Study duration (months):NR | Kodak DC-210 Photographer: “Trainee doctor” Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 12/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 1/2
Oliveira 2002^29^ Brazil Repeated Measure Funding: NR | 92 NR | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: NR Inclusion criteria: NR Exclusion criteria: NR Study duration (months): NR | Kodak DC265 Photographer: nurse Time between photograph and gold standard (days): <7 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 6/7 Reference test: 2/3 Data analysis: 1/2
Jolliffe 2001^30^ United Kingdom Repeated Measure Funding: National Health Service R&D grant | 138 144 | Age range: 15–94 years Gender: female 66%, male 34% Race/ethnicity: NR Condition characteristics: PSL Inclusion criteria: PSL Exclusion criteria: NR Study duration (months): NR | Sanyo HiFi video Photographer: Dermatologist Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: No | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 1/2
Jolliffe 2001^31^ United Kingdom Repeated Measure Funding: National Health Service Executive London R&D grant | 611 819 | Age range: 8 to 94 years Gender: female 76%, male 24% Race/ethnicity: NR Condition characteristics: PSL Benign Neoplasm - 635 Keratinocyte Carcinoma - 20 Dysplastic Nevi - 112 Actinic keratoses - 13 Melanoma - 9 Infectious - 10 Acneiform - 5 Rash/Other - 13 Eczematous - 2 Inclusion criteria: PSL Exclusion criteria: Genital lesions, mental impairment, fear of technical equipment Study duration (months): NR | Sanyo HiFi video Photographer: Dermatologist Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: No Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 6/7 Reference test: 2/3 Data analysis: 1/2
Lim 2001^32^ Australia Repeated Measure Funding: Australian Dermatology Research and Education Foundation | 23 27 | Age: NR Gender: NR Race/ethnicity: NR Condition Characteristics: Eczematous - 18 Benign Neoplasm - 9 Infectious - 12 Keratinocyte Carcinoma - 3 Acneiform - 6 Paulosquamous/Other - 5 Inclusion criteria: new skin condition Exclusion criteria: wart or acne Study duration (months): 3 | Kodak DC265 Photographer: Dermatologist Time between photograph and gold standard (days): ≤7 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 1/3 Data analysis: 0/2
Taylor 2001^33^ United Kingdom Repeated Measure Funding: NR | 188 NR | Age: NR Gender: NR Race/ethnicity: “42% of the conditions from pigmented pts” Condition characteristics (most common diagnoses in 127): Eczematous - 21 Keratinocyte carcinoma - 9 Papulosquamous/Other - 15 Benign Neoplasm - 69 Acneiform - 8 Infectious - 5 Inclusion criteria: New dermatology pts Exclusion criteria: NR Study duration (months): 3 | NR Photographer: Nurse Time between photograph and gold standard test: NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 13/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 2/2
Barnard 2000^34^ United States Repeated Measure Funding: NR | 50 “cases” | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: 8 skin cancer cases Inclusion criteria: NR Exclusion criteria: NR Study duration (months): NR | Nikon Fujix DS505, Nikon SLR Photographer: NR Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Braun 2000^35^ Switzerland Repeated Measure Funding: NR | 51 55 | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: PSL Benign Neoplasm - 37 Dysplastic Nevus - 3 Melanoma - 9 Keratinocyte Carcinoma - 4 Other -2 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): 6 | TDSC: Mitsubishi CCD Photographer: 6 dermatologists Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 2/3 Data analysis: 1/2
High 2000^36^ United States Repeated Measure Funding: Mayo Clinic and Foundation, Minnesota Academy of Family Physicians | 92 106 | Mean age (range): 39.7 years (10 months – 81 years) Gender: female 48%, male 52% Race/ethnicity: NR Condition characteristics: Benign Neoplasm - 35 Keratinocyte Carcinoma - 6 Actinic keratoses -2 Melanoma - 1 Infectious - 12 Acneiform - 8 Papulosquamous/Other - 25 Eczematous - 17 Inclusion criteria: NR Exclusion criteria: None Study duration (months): 1.5 | Sony DCS-F1 Photographer: Medical student Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Piccolo 2000^37^ Italy Repeated Measure Funding: Osterreichische Krebshilfe Steiermark, Graz, Austria | 40 43 | Mean age (range): 39.5 years (3–91) Gender: female 47.5%, male 52.5% Race/ethnicity: NR Condition characteristics: PSL Keratinocyte carcinoma - 3 Melanoma - 11 Benign Neoplasm - 29 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): 3 | TDSC: video camera and stereomicroscope Photographer: NR Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: No Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Krupinski 1999^38^ United States Repeated Measure Funding: USDA Rural Utilities Service, US Dept. of Commerce, Health and Human Services | 308 308 | Age, gender, and race/ethnicity: NR Condition characteristics: Melanoma - 4 Actinic keratoses - 20 Keratinocyte Carcinoma - 49 Dysplastic nevus - 16 Benign Neoplasm - 106 Infection - 20 Eczematous - 36 Papulosquamous/Other - 57 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): NR | Canon Powershot 600 Photographer: Medical students Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 2/3 Data analysis: 0/2
Lewis 1999^39^ United Kingdom Repeated Measure Funding: NR | 56 cases | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: NR Inclusion criteria: NR Exclusion criteria: NR Study duration (months): 7 | Kodak DC40 Photographer: NR Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 8/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 5/7 Reference test: 3/3 Data analysis: 0/2
Piccolo 1999^40^ Italy Repeated Measure Funding: NR | 66 66 | Mean age (range): 41.2 years (8–82) Gender: female 52%, male 48% Race/ethnicity: NR Condition characteristics: PSL Melanocytic- 57 Nonmelanocytic-9 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): 0.75 | TDSC: video camera and stereomicroscope Photographer: NR Time between photograph and gold standard (days): NR | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Tait 1999^41^ Australia Repeated Measure Funding: NR | 30 NR | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: NR Inclusion criteria: Visible skin lesion Exclusion criteria: NR Study duration (months): NR | Ricoh RDC 300 Photographer: NR Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 2/2 Index test: 6/7 Reference test: 2/3 Data analysis: 0/2
Whited 1999^42^ United States, US armed service personnel/veterans Repeated Measure Funding: Veterans Affairs Health Service R&D | 129 168 | Mean age (range): 61 years (22 to 82) Gender: female 2%, male 98% Race/ethnicity: white 80%, black 20% Condition characteristics: NR Inclusion criteria: Diagnostic uncertainty Exclusion criteria: Previous dermatology evaluation Study duration (months): NR | Fujix DS-515 Photographer: Research assistant Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Whited 1998^43^ United States, VA pts Repeated Measure Funding: NR | 12 13 | Age: NR Gender: NR Race/ethnicity: NR Condition Characteristics: Benign neoplasm - 2 Keratinocyte carcinoma - 7 Actinic keratoses – 1 Other – 1 No biopsy - 1 Inclusion criteria: Suspected skin cancer Exclusion criteria: NR Study duration (months): NR | Fujix DS-515 digital camera, 1280x1000 pixels Photographer: NR Time between photograph and gold standard test (days): 0 | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Kvedar 1997^44^ United States Repeated Measure Funding: Massachusetts General Hospital Dermatology Service | 116 123 | Mean age (range): 40 years (18–84) Gender: NR Race/ethnicity: NR Condition characteristics: NR Inclusion criteria: NR Exclusion criteria: Acne or warts cases Study duration (months): 2 | Kodak DCS 420 Photographer: Non- dermatologists Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 13/14 Sources of bias identified by QUADAS Selection: 2/2 Index test: 7/7 Reference test: 3/3 Data analysis: 1/2
Lyon 1997^45^ United Kingdom Repeated Measure Funding: NR | 100 100 | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: Eczematous - 12 Acneiform - 3 Infectious - 5 Other - 20 Benign Neoplasm - 41 Keratinocyte Carcinoma - 19 Actinic keratoses - 5 Inclusion criteria: Dermatology referral Exclusion criteria: NR Study duration (months): NR | DC-40 Kodak Photographer: Dermatology resident Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 8/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 4/7 Reference test: 3/3 Data analysis: 0/2
Zelickson 1997^46^ United States Repeated Measure Funding: NR | 29 30 | Age: NR Gender: NR Race/ethnicity: NR Condition characteristics: Rash-18 Lesion-12 Inclusion criteria: Nursing home resident with a skin condition Exclusion criteria: NR Study duration (months): NR | Sony CCD-TR400 video Photographer: Nurse Time between photograph and gold standard (days): <2 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
B. Live interactive studies (n=10)
Edison 2008^7^ United States Repeated Measure Both SAF and LI Funding: Federal Office for the Advancement of Telehealth, Health Resources and Services Administration | 110 110 | Mean age (range): 42 (7–92) Gender: female 69%, male 31% Race/ethnicity: white 85%, black 12%, Asian 2%, Hispanic 1% Condition Characteristics for 70: Actinic Keratosis - 10 Acneiform - 12 Benign Neoplasm - 19 Dysplastic nevus - 1 Infectious - 7 Eczematous - 8 Other – 13 Inclusion criteria: New pts on study days Exclusion criteria: NR Study duration (months): 18 | Camera: NR Photographer: NR Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 12/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 1/2
Baba 2005^17^ Turkey Repeated Measure SAF +LI Funding: NR | 228 242 | Mean age (range): 35 years (2–82) Gender: female 63%, male 37% Race/ethnicity: NR Condition characteristics: Acneiform - 41 Infectious - 54 Pre-malignant/Malignant- 2 Eczematous - 46 Benign Neoplasms - 45 Papulosquamous/Other - 54 Inclusion criteria: None Exclusion criteria: None Study duration (months): 2.3 | Mustek camera Photographer: Nurse Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Nordal 2001^47^ Norway Repeated Measure Funding: | 112 112 | Mean age (range): 40 years (17–82) Gender: female 51%, male 49% Race/ethnicity: NR Condition characteristics: Eczematous - 7 Acneiform - 1 Papulosquamous/Other - 6 Benign neoplasm - 1 Inclusion criteria: New dermatologic conditions Exclusion criteria: Surgical treatment, emergency cases and most nevi Study duration (months): NR | Sony CCD DXC 930P video Photographer: General practitioner Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 13/14 Sources of bias identified by QUADAS Selection: 2/2 Index test: 6/7 Reference test: 3/3 Data analysis: 2/2
Gilmour 1998^48^ United Kingdom Repeated Measure Funding: National Health Service | 126 155 | Age range: 3 month -83 years Gender: female 51%, male 49% Race/ethnicity: NR Condition characteristics: Eczematous - 55 Papulosquamous/Other - 37 Infection - 23 Acneiform - 12 Tumor - 20 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): 12 | Camera NR Photographer: General practitioner or trained assistant Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 6/7 Reference test: 2/3 Data analysis: 0/2
Lesher 1998^49^ United States Repeated Measure Funding: Tele- medicine Center of Medical College of Georgia | 60 68 | Age: ≥ 18 years of age Gender: NR Race/ethnicity: NR Condition characteristics: Eczematous - 17 Benign Neoplasm -12 Keratinocyte Carcinoma - 3 Actinic keratosis - 6 Infectious - 4 Acneiform - 11 Papulosquamous/Other -15 Inclusion criteria: Adults with skin condition Exclusion criteria: NR Study duration (months): NR | VC TK-1280U, Panasonic WV-E550 Photographer: NR Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 11/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Loane, 1998^50^ United Kingdom Repeated Measure Funding: National Health Service | 351 427 | Mean age (range): 41 years (5 months-89 years) Gender: female 55%, male 45% Race/ethnicity: NR Condition characteristics (preliminary results): Tumor - 78 Eczema - 54 Infection - 28 Benign Neoplasm - 21 Acneiform - 13 Papulosquamous/Other - 42 Inclusion criteria: Dermatology referral Exclusion criteria: NR Study duration (months): 18 | VC7000 video, KY-F55B JVC video Photographer: General practitioner Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 6/7 Reference test: 2/3 Data analysis: 0/2
Lowitt 1998^51^ United States, US armed service personnel/veterans Repeated Measure Funding: Baltimore Research and Education Foundation | 102 130 | Median age (range): 65 (range 23 to 85) Gender: male 95%, female 5% Race/ethnicity: white 60%, black 40% Condition characteristics: Acneiform - 17 Eczematous - 33 Infectious - 9 Papulosquamous/Other -17 Benign Neoplasm - 36 Premalignant Tumor - 16 Malignant Neoplasm - 6 Inclusion criteria: consecutive dermatology outpts Exclusion criteria: Pts transported by stretcher Study duration (months): 2 | 3-CCS JVC video Photographer: Nurse escort Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: Yes Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 12/14 Sources of bias identified by QUADAS Selection: 2/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Phillips 1998^52^ United States Repeated Measure Funding: NR | 51 107 | Mean age: 47 Gender: female 84%, male 16% Race/ethnicity: NR Condition characteristics: Benign Neoplasm - 81 Keratinocyte Carcicnoma - 5 Melanoma - 1 Premalignant - 14 Dysplastic Nevi - 5 Inclusion criteria: NR Exclusion criteria: NR Study duration (months): NR | Panasonic video, Canon video Photographer: Dermatologist Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: Yes | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2
Oakley 1997^53^ New Zealand Repeated Measure Funding: Waikato Information Services Department of Health | 104 135 | Age range: 2–86 years, Gender: female 60%, male 40% Race/ethnicity: NR Condition characteristics: Eczematous - 17 Benign Neoplasm - 24 Malignant Neoplasm - 25 Actinic Keratosis - 15 Infectious - 7 Acneiform - 13 Melanoma - 4 Papulosquamous/Other -30 Inclusion criteria: New dermatology pts Exclusion criteria: NR Study duration (months): NR | Canon VC-C1 video, Vtel system Photographer: Dermatologist Time between photograph and gold standard (days): 0 | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 9/14 Sources of bias identified by QUADAS Selection: 1/2 Index test: 6/7 Reference test: 2/3 Data analysis: 0/2
Phillips 1997^54^ United States Repeated Measure Funding: NR | 60 79 | Mean age (range): 37 years (1–68) Gender: female, 60%, male 40% Race/ethnicity: white 73%, black 25% Condition characteristics: Eczematous - 14 NMSC - 4 Actinic keratosis - 5 Acneiform - 9 Infection - 8 Melanoma - 1 Benign Neoplasm - 26 Papulosquamous/Other -12 Inclusion criteria: Referral Exclusion criteria: NR Study duration (months): NR | Picture-Tel System 4000 video, Elmo model MN401X dc Photographer: trained nurse Time between photograph and gold standard (days): NR | Diagnostic Accuracy: No Diagnostic Concordance: Yes Management Accuracy: No Management Concordance: No | Overall QUADAS score: 10/14 Sources of bias identified by QUADAS Selection: 0/2 Index test: 7/7 Reference test: 3/3 Data analysis: 0/2