# ABBREVIATIONS

CD: Clinic dermatology/clinic dermatologist; in-person dermatology care/in-person dermatologist
CID: Contact immersion dermatoscopy
DoD: Department of Defense
DSC: Dermatoscopy
Hrs: Hours
k: Kappa coefficient
KC: Keratinocyte Carcinoma (BCC, SCC, Keratoacanthoma, SCC-in-situ)
KQ: Key question
LI: Live interactive teledermatology
95%CI: 95 percent confidence intervals
NPSL: Non-pigmented skin lesions
NA: Not applicable
NR: Not reported
PLD: Polarized light dermatoscopy
PSL: Pigmented skin lesions
Pt: Patient
RCT: Randomized controlled trial
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
SAF: Store and forward teledermatology
SD: Standard deviation
SL: Skin lesions
TD: Teledermatology/teledermatologist
TDSC: Teledermatoscopy
UC: Usual care (in-person dermatology)
VA: Veterans Affairs
vs.: Versus