# PEER REVIEW COMMENTS AND AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Yes | NA
Yes | NA
2. Is there any indication of bias in our synthesis of the evidence?
No | NA
No | NA
3. Are there any published or unpublished studies on the use of teledermatology for the diagnosis and management of skin conditions (including studies of clinical outcomes, patient satisfaction, or associated costs) that we may have overlooked?
None that I am aware of | NA
None that I’m aware of | NA
4. Additional comments
The current format serves as a comprehensive review of the status of the literature. | Thank you
Quality of teledermatology how is the quality of the test itself ensured? | We assume the reviewer is asking about the quality of the picture image. We did not specifically look at image techniques but we only included studies published after 1990 to insure technical relevance.
EXECUTIVE SUMMARY:
In the summary for KQ4, clarify the statement “The long duration to achieve definitive dermatologic care … is not consistent with current VA practice …” | We have clarified this statement.
In the executive summary I would prefer to see the Key Question stated followed by the conclusion. Following that, there could be the brief discussion of the results from the literature (that supports that conclusion). | Thank you for the suggestion. We have placed the conclusions immediately following the questions.
In “Methods” state that all-pediatric studies were excluded | To shorten the Executive Summary, we have deleted the inclusion/exclusion details. We have clarified the inclusion/exclusion criteria for studies in the full report.
KQ3 – Clarify the “clinical outcomes of interest” | We have specified the outcomes of interest.
Conclusion – As worded, the conclusion may be misinterpreted as overly negative; the true comparison needed for many populations is between telederm and primary care diagnosis and management | We agree that this type of study is needed and have clarified the conclusion statements to reflect that.
Interpretation of ‘raw’ comparisons – I’m not sure what it means that ‘weighted mean absolute difference was 19% better for UC than teledermatology’ (page v) – perhaps include some concrete examples to make the numbers more meaningful or at least place them in some context (e.g., for other comparisons of diagnostic tests) | These comparisons have been reworded to clarify that these differences are differences in accuracy rates.
Define abbreviations before using them | We have made this change.
Not sure why inclusion was limited to randomized trials for questions 1–2; does this mean that retrospective reviews of telederm consults were not included? (page iii) | Inclusion was for controlled trials (not randomized); most were repeated measure design. Retrospective reviews were included if a control group was utilized. This has been clarified in the inclusion/exclusion criteria.
Did teledermoscopy improve accuracy of teledermatology to better than UC, or at least much closer? (page v) | This statement has been revised to clarify that accuracy improved, but still was not better than usual care.
Conclusion should probably include the information that the accuracy and concordance for malignancies may not be acceptable (page xlvii) | This information has been added.
INTRODUCTION/BACKGROUND:
Do you have data to support the statement “SAF is the more widely used form of teledermatology in the VA”? | An informal survey of dermatology chiefs is included in the introduction.
METHODS:
On the literature flow diagram, clarify the “other” and “not eligible study setting” exclusion criteria | We have modified the study exclusion criteria, eliminating these two criteria.
List the inclusion and exclusion criteria for studies (bulleted format) | These have been reformatted into bullet structure.
Inclusion/exclusion criteria – could have used more explanation | These are now described.
Clarify the asterisk on the search results (657 references) | The explanation was inadvertently deleted from the draft sent for review; please see updated flow diagram.
Clarify why 1990 was chosen as the start date for the review | This has been clarified in the text.
Difficult for the reader to interpret the QUADAS scores – how do these compare with, say, the quality scores of primary studies in other systematic reviews? | There is no direct comparison. The QUADAS scale is, however, the most relevant for assessing the quality of studies of diagnostic tests.
RESULTS:
Did we compare US vs. non-US studies? Do the results vary? | The results of the US vs. non-US studies were similar. We have revised the results section putting more emphasis on VA/DoD studies.
KQ2a – the conclusion is based on two studies from one center; it may be worth noting that the result may be hard to generalize to other health care setting/populations in active programs | This information has been added.
KQ5 – “Several publications have described …” - please make sure you include the VA Teledermatology Ops Manual | The references for this statement have been clarified – the Ops Manual is cited.
KQ5 – “Because store and forward is the method used … “ – I don’t think this is true based on coding data | An e-mail survey of chiefs of VA dermatology services was conducted to confirm that SAF is more commonly used than LI in the VA setting.
CONCLUSIONS:
Make the conclusions relevant to VA dermatology – readily usable by policy makers and clinicians | The conclusion section has been revised to focus on VA relevance.
How do the findings apply to situations with no available in-person dermatology? Is it possible to group studies based on the setting (very rural and urban)? | The conclusion section has been revised to address this.
FUTURE RESEARCH:
Emphasize gaps in the current research – be specific, prioritize | The future research section has been revised to address specific needed study outcomes and settings.
OVERALL:
Consider changing the title to indicate that report is focused on adult population | Twenty of the included studies enrolled a mixed (adult/pediatric) population; it would not be possible to report only the results from the adults included in those trials.
A particular strength of this review is the overall framework that examines the diagnostic test(s) ‘teledermatology’ with respect to measurement characteristics, effects on patient care processes and outcomes, and organizational features related to successful implementation | Thank you.
The quality of this review is high in that it is clear, accurate, completed, and clinically relevant … the study questions were well-defined and important, the literaturesearch appeared comprehensive, the methods of abstraction were adequate, judgments of methodological quality were included, the pooling of results seemed sensible and conservative, and the conclusions were reasonable. | Thank you.
No reference is made to the 2006 AHRQ Telemedicine review that covered teledermatology. | This reference has been added to the Summary and Discussion section.
It is usually acknowledged that there is a lack of concordance between face-to-face dermatology consultations and the difference between face-to-face and teledermatology is usually couched in this context. | A statement has been added to the Future Research Recommendations section.
Programs usually acknowledge the issues with pigmented lesions and expedite referral for these with teledermatology (a “triage” in which pigmented lesions and suspected malignancies are seen more rapidly) | We have noted the inferior management accuracy rates for malignant and pre-malignant lesions in our conclusion statements for Key Question 2 and in the Conclusions Section.
It is not clear whether the differences noted in the studies result in altered clinical outcomes for patients or are hypothetical. | We agree. As noted in the results for Key Question 3, there are few studies that directly address clinical outcomes.
Given the profound challenges with providing dermatology, especially in rural areas, issue of access are often that of teledermatology versus a general practitioner – this was alluded to but more emphasis could be placed on the issues with providing face-to-face dermatology nation-wide. | We have added the need for research of this nature to the Conclusion section.
A further model of teledermatology is that of using a dermatology trained nurse practitioner. | None of the studies identified for the review evaluated this model. The need to include dermatology trained nurse practitioners was added to the Future Research section.