# DATA EXTRACTION FORM

Data Extraction Form