# SEARCH STRATEGY

Database: Ovid MEDLINE(R) <1950 to April Week 3 2009>
Search Strategy:
1 | (remote: adj2 consult:).tw. (158)
2 | exp electronic mail/ (1025)
3 | exp Telecommunications/ (36778)
4 | exp remote consultation/ (2661)
5 | telemed$.mp. or exp Telemedicine/ (10571)
6 | exp telepathology/ (504)
7 | or/1-6 (37311)
8 | derm$.mp. or exp dermatology/ (180688)
9 | 7 and 8 (534)
10 | telederm$.mp. (269)
11 | 9 or 10 (576)
12 | limit 11 to yr=”1990 -Current” (559)

PubMed search (06-03-09):

(((remote* AND consult*[tw]) OR (electronic mail[mh]) OR (telecommunications[mh]) OR (remote consultation[mh]) OR (telemed* OR telemedicine[mh]) OR (telepathology[mh])) AND (dermatol* OR dermatology[mh])) OR (telederm*) [587]

Search results from OVID MEDLINE (556 references) and PubMed (587 references) were combined, resulting in a total of 657 unique references