# SUMMARY AND DISCUSSION

Our findings indicate that reported prevalence of TBI/PTSD varies widely. Differences in populations, study methodology, trauma severity and etiology, and methods and definitions of ascertainment weaken the strength of the evidence and do not permit accurate prevalence estimates, particularly for patient subgroups of greatest interest to the Department of Veterans Affairs. The three largest studies involving U.S. military personnel and veterans of OEF/OIF, while based on different study populations and survey methods, had relatively consistent results. Results of these three studies indicated that TBI/PTSD (the majority in the RAND study likely to have mTBI/PTSD) occurred in approximately 5% to 7% of individuals. Among individuals who reported a history of probable TBI, probable PTSD was identified in 33% to 39%. Prevalence varied widely in other studies, likely due to different methods to define and identify cases of TBI and PTSD. We emphasize that these factors can have a profound impact on estimates for prevalence, severity, natural history, and response to treatment for these conditions. In particular, methods that utilize highly sensitive but less specific screening instruments that incorporate self-reported outcomes that can be influenced by financial compensation are likely to increase prevalence estimates and over-diagnose individuals with milder conditions. These points are evidenced by the recent commentary and letters of response published in the New England Journal of Medicine.23,28 Similarly, studies that enroll subjects hospitalized or receiving medical care specifically for their trauma are likely to overestimate prevalence. Because these individuals may differ substantially in many ways (both known and unknown) from individuals with less severe TBI/PTSD and/or cases detected through other screening methods/thresholds, caution should be taken when extrapolating findings from one population to another.

We were unable to identify any studies that evaluated the accuracy of diagnostic tests for individuals with suspected mTBI/PTSD. Furthermore, we were unable to identify any randomized controlled trials and only two case reports related to efficacy of treatment specifically for mTBI/PTSD. Therefore, there is insufficient evidence required to make high quality diagnostic and treatment recommendations pertinent to our key questions. While we identified a large number of ongoing studies related to TBI and PTSD, none are likely to provide high-quality, direct evidence pertaining to key questions 2 and 3 (methods of assessment and treatment). We have provided some recommendations below for the general design, conduct, and outcome measurements for future research studies.

## CONCLUSIONS

The reported prevalence of TBI/PTSD varies widely, likely depending on patient characteristics, trauma etiology, disease definition, and ascertainment method. There is no information on the diagnostic accuracy of commonly used tests to assess history of mTBI or current PTSD when both conditions are present. There is no information on the effectiveness and harms of therapies in adults with mTBI/PTSD. There is considerable on-going research in this area. However, long-term prospective observational studies are needed that use standardized, validated measures of TBI (particularly mTBI) history and PTSD to determine TBI/PTSD prevalence, severity, and outcomes. Among military personnel, pre-deployment as well as post-deployment assessment should be obtained using objective measures that limit ascertainment, recall, or reporting bias. Outcomes according to clinically-relevant patient characteristics, trauma etiology and subtypes, and time from trauma are required. Diagnostic accuracy studies are needed that utilize established quality methods as reported in the STARD initiative47 and recommended in the QUADAS report.86 Adequately powered, high-quality randomized, controlled treatment trials in populations of interest are required to evaluate the clinical effectiveness and harms of potential therapeutic options, especially among individuals with mTBI/PTSD.

## FUTURE RESEARCH RECOMENDATIONS

Long-term prospective observational studies are needed that use standardized and validated measures of TBI history and PTSD to determine prevalence, severity, and outcomes of TBI/PTSD. There is a clear need for researchers to come to consensus on the definitions and measures that will be used consistently across studies in order to facilitate comparison of results. Among military personnel, pre-deployment as well as post-deployment assessment should be obtained using objective measures that limit ascertainment, recall, or reporting bias. Outcomes according to clinically relevant patient characteristics, trauma etiology and severity, and time from trauma are required. Diagnostic accuracy studies are needed that utilize established quality methods such as QUADAS. Randomized controlled treatment trials in populations of interest are required to evaluate the effectiveness and harms of potential therapeutic options, especially among individuals with mTBI/PTSD. Research specific to care coordination and treatment planning between specialty clinics and providers should also be considered.

Future research should be devoted to addressing these question using more representative samples and longitudinal methods. Methodologically, we recommend that future research in this area adhere to guidelines for reporting observational studies as report in the Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) Statement.87 As most research relies on samples with probable TBI history recruited from hospital settings, future investigations should include both nationally representative samples, as well as specific samples of interest, such as OEF/OIF veterans or populations seeking services primarily for trauma exposure (e.g., those seeking mental health services, victims’ advocacy, or legal services as victims of crime). Future research should develop innovative methods to obtain information necessary for assessing the occurrence of TBI near the time of injury without relying on subject recall or hospital admission to identify patient populations, especially given the suspected low rates at which those with potential mTBI seek emergency medical treatment.

Research optimizing the diagnostic accuracy of assessment for both TBI history and current PTSD in representative populations using gold-standard assessments is of paramount importance. Accuracy is contingent upon research clarifying diagnostic debates regarding how to best assess these conditions when they co-occur. Additionally, little is known regarding the trajectory of symptoms over time for those with either TBI history or current PTSD, and whether outcomes differ among individuals classified as having mTBI/PTSD versus those with just PTSD (especially after controlling for potentially confounding variables). Longitudinal research is needed to assess the degree of overlap in these conditions and long-term outcomes using gold-standard instruments with increasing time from the traumatic event. Future research (and clinical care) would benefit from studies that adhere to the Standards for Reporting of Diagnostic Accuracy (STARD) statement.47

Finally, further research is needed that directly compares prevalence of TBI/PTSD among samples matched on important domains such as the type of traumatic events to which individuals were exposed (e.g., combat vs. MVC, physical assault, intimate partner violence), the number and severity of TBI events, demographic characteristics (e.g., gender, race, age), and methods of assessment. Results should be stratified by these clinical characteristics of interest. Furthermore, among military personnel, assessing symptomology prior to deployment and then immediately post-deployment could provide useful information regarding causation.

In regard to the treatment of PTSD among individuals with a history of mTBI, we recommend first evaluating the effectiveness of empirically supported treatments (ESTs) for PTSD (e.g., prolonged exposure therapy and cognitive processing therapy) among individuals with a history of mTBI. Ideally, individuals would be stratified by mTBI status (mTBI/PTSD vs. PTSD without mTBI), then randomized to either the EST or a minimal contact control condition. This design would enable researchers to examine the efficacy of the treatment among adults with mTBI/PTSD and to evaluate differential outcomes between participants with mTBI/PTSD and participants with PTSD but no mTBI history. If the two groups have equivalent outcomes on a variety of measures (PTSD symptomology, functioning, and quality of life), we recommend future research focus on improving outcomes for all individuals with PTSD, rather than focusing specifically on treatments for those with a history of mTBI. Within such a trial, we also suggest extracting treatment process data that would allow researchers to examine whether adults with mTBI/PTSD have more difficulty with tasks related to memory and attention (e.g., homework completion, engagement in imaginal exposure) than individuals with PTSD but no mTBI history. In the case of differential outcomes, such process data would allow researchers to begin to examine factors that may have contributed to lower levels of recovery among individuals with mTBI/PTSD. If memory or attentional problems do contribute to differential outcomes, we suggest the development and evaluation of a set of compensatory strategies that can be used in conjunction with existing ESTs to improve outcomes (e.g., the use of a personal digital assistant to remind individuals to complete homework and track anxiety levels). Of note, given the concentration difficulties associated with PTSD, such strategies may be benefecial for all veterans undergoing an EST for PTSD. Finally, if adding compensatory strategies to existing ESTs for PTSD does not improve outcomes among individuals with mTBI/PTSD, researchers should look to more substantially alter existing ESTs or begin to develop novel interventions.