# RESULTS

## LITERATURE FLOW

The combined library contained 1107 citations, of which we reviewed 358 articles at the full-text level. From those 358 articles, we identified 31 unique studies (described in 37 references) that addressed the key questions (Figure 1). Studies were excluded because they were published prior to 1980, included more than 10% of participants less than age 18 years, did not enroll individuals with history of probable TBI or probable PTSD, or did not present results in a manner that addressed the key questions. A study by the RAND Corporation was included under primary results (not depicted in diagram). The RAND study assessed both probable TBI history and PTSD in a large, presumably nationally-representative sample of U.S. military personnel. While it was not published in a peer-reviewed journal, the report was peer-reviewed, published by the RAND Corporation, and is available on the RAND website.5 An additional five studies were included under secondary results (not depicted in flow diagram).

Figure 1 Published data search and selection

*Search results from PubMed (700), PsycInfo (552) and REHABDATA (123) were combined, removing duplicate entries (268).

† “Probable” TBI and PTSD are defined on page 6 and include positive “screens” based on self-report measures as well as clinical diagnoses.

## Key Question #1. What is the observed prevalence of comorbid TBI and PTSD? Does the reported prevalence vary by study population, trauma etiology, TBI severity, or methods of case ascertainment?

### Summary of Findings

There were 31 unique studies that reported prevalence of TBI/PTSD. We also included a telephone survey of a national sample of OEF/OIF veterans conducted by the RAND Corporation that was peer reviewed and published electronically on their website yielding a total of 32 unique studies. Studies varied considerably by design, population, trauma etiology and severity, presence of pain or mental health disorders other than PTSD, methods and timing of case ascertainment, and definitions of disease/injury and severity. Additionally, while clinically relevant baseline characteristics were sometimes reported, prevalence of TBI/PTSD was rarely stratified by these variables. Therefore, results could not be pooled across studies, few patterns could be discerned, and reliable outcome estimates could not be obtained for key patient groups. A few studies uniquely enrolled or excluded subjects with a particular characteristic (e.g., men; military veterans). We attempted to separately describe findings from studies that were unique to the military or veteran population.

### Study Details

(See Table 1; Appendix D)

#### Description of studies reporting prevalence of TBI/PTSD

Thirty-one unique published studies meeting inclusion criteria and enrolling between 10 and 2525 participants (majority less than 200) reported prevalence of TBI/PTSD among participants.21,22,52–81 Additionally, the study by the RAND Corporation, which enrolled 1965 participants, reported prevalence of TBI/PTSD.5 The two largest of the published studies and the RAND report involved U.S. military personnel.5,22,55 A summary of characteristics across published studies is presented in Table 1. Details on study design, population characteristics, assessment methods, and prevalence data for each of the published studies and, separately, the RAND study, are tabulated in Appendix D (Tables 1 and 2).

Table 1 Summary of study characteristics for n=31 published unique studies reporting prevalence of TBI/PTSD

Characteristic | Range (# of participants, percents, or means) | # of studies reporting
Range of enrolled subjects | 10 to 2525 | 31
Range of enrolled subjects in studies in which all subjects were U.S. veteran and/or active duty | 43 to 2525 | 8
Mean age | 25 to 52 | 27
Gender, female - % | 0 to 83 | 29
Race, white - % | 16 to 92 | 7
Race, non-white - % | 6 to 84 | 7
Education, less than high school graduate - %^*^ | 3 to 48 | 4
Education, high school graduate or more - %^*^ | 34 to 85 | 5
Education, any college - %^*^ | 25 to 49 | 3
TBI severity (Studies not reporting TBI severity n=8 )
TBI, mild - % | 19 to 100 (11 studies 100%) | 21
TBI, moderate - % | 10 to 100 (1 study 100%) | 12
TBI, severe - % | 17 to 100 (3 studies 100%) | 12
Trauma etiology (Studies not reporting etiology n=4 )
Motor vehicle crashes - % | 17 to 100 (6 studies 100%) | 22
Assaults - % | 3 to 58 | 11
Falls - % | 8 to 39 | 11
Combat-related injuries - % | 25 to 100 (4 studies 100%) | 8
Work-related injuries - % | 3 to 15 | 4
Sports/leisure-related injuries - % | 14, 28 | 2
Terror-related injuries - % | 50 | 1
Other/not defined | 14 to 30 | 5
Presence of pain or mental health disorders other than PTSD (Studies not reporting n=17)
Pain, including headaches - % | 11 to 100 (1 study 100%) | 5
Depression and/or depressive symptoms - % | 9 to 90 | 8
Substance use disorders - % | 14 to 42 | 3
Anxiety disorders other than PTSD or anxiety symptoms unspecified - % | 9 to 60 | 3
Obsessive-compulsive disorder - % | 15, 100 (1 study 100%) | 2
Panic - % | 14 | 1
Depression and anxiety disorders unspecified - % | 71 | 1
Study type
Cohort | 28 to 307 | 14
Case-control | 144 | 1
Cross-sectional | 43 to 2525 | 15
Case series | 10 | 1

* U.S. only

Table 2 Prevalence of PTSD among individuals with TBI, by trauma etiology

Author, year | Injury etiology | TBI severity | % of TBI subjects with PTSD
Military-related Injuries
Gaylord et al., 2008^52^ | Military, blast and burn (100%) | Mild 100% | 45%
Hoge et al., 2008^22^ | Military, blast (75%) | Mild 100% | 33%
Koenigs et al., 2008^54^ | Military (100%) | Penetrating 100% | 32%
Mora et al., 2009^81^ | Military, blast and burn (100%) | Mild 95% Severe 5% | 35%
RAND, 2008^5^ | Military (100%) | Not Reported | 34%
Ruff et al., 2008^53^ | Military, blast (100%) | Mild 100% | 66%
Non-military injuries *
Bryant et al., 1998^70^ | Motor Vehicle Crashes (MVC) (100%) | Mild 100% | 24%
Bryant et al., 1999b71 | MVC (100%) | Mild 100% | 20%
Gil et al., 2005^60^ | MVC (84%) | Mild 100% | 14%
Hickling et al., 1998^72^ | MVC (100%) | Not reported | 56%
Jones et al., 2005^61^ | MVC (100%) | Mild 100% | 32% at time 1 19% at time 2
Schwartz et al. 2007^56^ | MVC (82%) | Mild 32% Moderate 21% Severe 47% | 42%

* Excluded 1 study reporting TBI/PTSD among a population of patients with obsessive-compusive disorder (Berthier et al., 2001)65

#### Study design and location

Many studies were single center and nearly all assessed TBI/PTSD status in patients who had been previously hospitalized or received care in an emergency room specifically related to their trauma. Because individuals who have experienced a TBI, especially mTBI, or who have PTSD may not present to medical facilities for TBI/PTSD-related symptoms, findings from most of the identified studies may not provide accurate population estimates (even for military veterans) for the prevalence of both conditions, particularly mTBI/PTSD. One study (n=144) utilized a case-control design;56 the remaining were mostly cohort or cross-sectional studies. One small case series enrolled ten subjects.65 The majority of studies were conducted in the U.S. (n=16),21,22,52–55,57,58,63,67,71–74,79,81 followed by the United Kingdom (n=6),61,62,64,77,78,80 Australia (n=4),59,68–70 Israel (n=3),56,60,66 and Denmark (n=1).76 The RAND report described a cross-sectional U.S. national telephone survey of OEF/OIF veterans.5

#### Patient demographic characteristics

Eight of the American studies and the RAND report evaluated U.S. military personnel.5,22,52–55,73,79,81 In 24 of the 29 studies reporting gender, the majority of subjects were male (ranging from 53% to 100%). One U.S. study evaluating veterans was exclusive to males.73 Among the 27 studies reporting mean age, ages averaged between 30 and 40 years; two studies had mean ages greater than 50 years.73,79 Among the seven studies reporting race, most subjects were white (range 16% to 92%).57,58,63,67,71,72,79 One study (n=200) included mostly non-white subjects (84%).67 Most U.S. subjects had at least a high school education. The RAND study evaluated a military active duty and veteran population that was mostly male (89%), mostly white (66%), and had a median age of 30.^5^

#### TBI severity

Twenty-four studies21,22,52,53,55,56–61,63,65,67–70,73,75–81 included subjects with a history of mTBI, 12 exclusively.21,22,52,53,55,59–61,68–70,76 The percentage of subjects who experienced a moderate TBI ranged from 10% to 40% in 10 studies56–58,65,67,73,75,78–80 and 100% in one study.74 The percentage of subjects who experienced a severe TBI ranged from 5% to 62% in eight studies56–58,65,78–81 and 100% in three studies.62,64,66 Only two studies did not report levels of TBI severity.71,72 The RAND study did not measure information pertinent to TBI severity.5 However, by virtue of the study population, and the substantial proportion of respondents reporting they had received no medical care related to a TBI, the majority of individuals reporting a history of TBI were likely to have incurred mTBI.

#### TBI etiology

Injuries related to combat (blast and non-blast sources) accounted for most of the trauma in the studies of U.S. military personnel.22,52–55,73,79,81 Combat-related trauma was reported exclusively in five of the eight U.S. studies involving soldiers and veterans.52–54,73,81 Combat injury was noted in only one study outside the U.S., accounting for 25% of trauma cases in an Israeli study.66 Trauma resulting in TBI due to motor vehicle crashes (MVC) was reported in 22 studies, ranging from 17% to 100% of the cases.21,22,55,56–58,60–62,64–72,74,77,78,80 Five of the studies included only trauma due to MVCs.61,65,69,70,72 Trauma due to assaults (range 3% to 58%) was reported in 10 studies57,62,64,67,68,71,74,75,78,80 and trauma due to falls (range 8% to 39%) was also reported in 10 studies.21,22,55,56,58,62,64,74,78,80 The case-control study, conducted in Israel, compared trauma due to terror (blast or gunshot) to non-terror trauma, mainly as a result of MVCs.56 The RAND study did not precisely identify TBI etiology.5 The survey asked respondents about TBI-related events that occurred while deployed.

#### Presence of pain or mental health disorders other than PTSD

Pain, including headaches, was reported in five studies (11% to 100% of participants).22,53,68,69,76 Few studies reported the prevalence of any mental health disorders other than PTSD. Depression (or depressive symptoms) was the most commonly reported mental health condition, reported in nine studies.22,57,63,65–67,71,75,80 Prevalence was less than 50% in most studies. One case series study involved participants (n=10) of which 90% had been diagnosed with obsessive-compulsive disorder.65 Substance use disorder was reported in three studies, ranging from 14% to 42% of participants,63,71,73 followed by anxiety disorders other than PTSD (9% to 60% of participants) reported in four studies,57,63,71,80 and panic disorder (14% of participants) reported in one study.71 A major purpose of the RAND study was to assess the prevalence of depression in the OEF/OIF veteran population. Approximately 14% of the study population was deemed to have probable major depressive disorder.5

#### Definitions and ascertainment methods

Studies varied widely in their operational definitions of TBI and PTSD and the methods and timing of assessment. Methods of case ascertainment included medical records review, clinical interviews, varying scores on the Glasgow Coma Scale, self report of loss of consciousness and/or altered mental status, and receiving treatment for a head injury at a hospital. Several studies based case inclusion criteria on positive responses to TBI and/or PTSD screening measures. For example, a single cross-sectional administrative database study of 126 veterans (gender, race, and age not reported) used a positive screen on the VA 4-item TBI screening instrument to enroll participants.53 In this study, the prevalence of TBI/PTSD was determined by assessing the percentage of individuals reported to have a probable history of TBI based on this instrument who also scored >50 on the self-reported Post-traumatic Stress Disorder Checklist (PCL). The RAND study similarly used screening instruments to assess history of TBI (the Brief Traumatic Brain Injury Screen [BTBIS]) and PTSD (PCL-Military Version [PCL-M]).5 The time since trauma when assessments were conducted was frequently not reported. However, three longitudinal studies followed hospital TBI cohorts over time and assessed for PTSD at various reported time points since injury.58,61,70

### Prevalence of TBI/PTSD

(See Figures 2 and 3; Appendix D)

#### Reported prevalence of TBI/PTSD across study populations

Figure 2 displays the range of reported TBI/PTSD prevalence levels across study populations; studies involving U.S. military populations are listed first. As shown, the range of TBI/PTSD prevalence was broad (from 0% to 70%). Across all 31 published studies, plus the RAND study, the majority (n=22) reported prevalence levels of 20% or less. The few studies with values of 50% or more were small and/or had highly non-representative study populations (e.g., patients with obsessive-compulsive disorder).53,65,73 Among the U.S. military/veteran studies, the three largest, most representative studies reported TBI/PTSD prevalence between 5% and 7%.5,22,55 Each of these studies used similar self-report screening measures to assess both history of mTBI and current PTSD; thus, these numbers do not reflect actual diagnoses of mTBI or PTSD, which is almost certainly lower than the prevalence estimates based on the reported initial screening results. Among the four largest non-military studies, prevalence ranged from 8% to 30%.58,59,63,67 Two of these studies involved populations that were comprised entirely of individuals with a history of TBI.58,63 The other two involved clinic/hospital cohorts, identified diagnoses that were mostly mild and moderate TBI, and assessed for PTSD using a structured clinical interview (e.g., Clinician-administered PTSD Scale [CAPS], Structured Clinical Interview for the DSM-IV [SCID]) which are considered to be more stringent than the frequently used self-report PTSD screening measures (e.g., PTSD Checklist [PCL], Impact of Events Scale [IES]). Both of these studies reported TBI/PTSD prevalence of 8% in their study populations.59,67

Figure 2 Prevalence of TBI/PTSD across study populations

* Study populations included participants with and without TBI history. Unless indicated, all other study populations were comprised exclusively of participants with TBI history.

** Study population was comprised exclusively of participants with PTSD.

Figure 3 Prevalence of PTSD among study participants with a history of mTBI

#### Reported prevalence of TBI/PTSD by level of TBI severity

Prevalence of TBI/PTSD may differ by TBI severity. In the studies that involved study populations that were homogenous by TBI severity, or that reported PTSD prevalence stratified by TBI severity, prevalence of PTSD ranged from 0% to 89% in participants with a history of mTBI,21,22,52,53,55,57,59–61,65,67–70,75,76,79–81 8% to 55% for those with a history of moderate TBI,57,65,67,74,75,79,80 and 0% to 19% for those with a history of severe TBI.57,61,64–66,79,80 Because the emphasis of this evidence review was on mTBI, we were particularly interested in prevalence of PTSD among individuals with a history of mTBI. Figure 3 depicts the prevalence of mTBI/PTSD across studies, again listing studies of U.S. military and veteran populations first. It is important to emphasize the different denominator used in the prevalence values reported in Figure 3 (# with mTBI/PTSD/# of individuals with mTBI) in contrast to Figure 2 (# with TBI/PTSD/# of individuals in study with or without TBI).

Two points should be noted when examining the studies in this way. First, when restricting the denominator to individuals with a positive history of mTBI, we are asking a slightly different question about prevalence. In Figure 2, we examine prevalence of TBI/PTSD across entire study populations while, in Figure 3, we examine prevalence of PTSD in individuals with a history of mTBI. Both questions were of interest for this review. However, when examining prevalence of PTSD among individuals with a history of mTBI, the reported prevalence values tend to be higher, which could be due to differential exposure among these individuals or other selection biases. Note that some values in Figure 3 are the same as in Figure 2 because these studies involved populations in which all participants had a history of mTBI.21,22,52,53,55,59,60,61,68,69,70,76

Second, the prevalence of PTSD in U.S. military/veteran study populations with a history of mTBI tends to look somewhat higher than prevalence of PTSD in the civilian study populations; however, the assessment methods varied and could account for these differences. The two large U.S. military studies reported PTSD prevalence levels of 33% and 39% among those with a history of mTBI.22,55 These values are consistent with the findings of the RAND study, which reported a PTSD prevalence of 34% among those with history of TBI (note that the RAND study was not exclusive to mTBI though likely predominantly identified mTBI).5 Each of these studies used similar self-report screening measures for both mTBI and PTSD; thus, these numbers do not reflect actual diagnoses of mTBI or PTSD. In contrast to these studies, the largest of the civilian studies reported PTSD prevalence between 12% and 27%.59,60,67,68,70 While lower than prevalence values in the military/veteran studies, all five of these studies involved patients specifically treated for trauma in a hospital or clinic and utilized a structured clinical interview to assess PTSD. No studies provided estimates of mTBI/PTSD prevalence in civilians who were not specifically treated in a hospital or clinic for TBI.

#### Reported prevalence of TBI/PTSD by trauma etiology

In addition to variation by TBI severity, prevalence of TBI/PTSD would be expected to vary by important exposure characteristics including type of trauma, time since trauma exposure, and number of trauma exposures. Most studies described populations with diverse trauma sources. To examine potential differences in TBI/PTSD prevalence by military versus non-military etiologies, we compared studies that reported prevalence of PTSD in populations with TBI, if they: 1) reported prevalence explicitly by etiology; or 2) reported prevalence in populations in which ≥ 75% had a single etiology. The following table lists these studies organized by military and non-military etiology. We use the term ‘military’ and further describe the percent by etiology of blast or burn (presumed combat) because in some instances military trauma may not be due to direct combat injuries (e.g., non-combat motor vehicle crashes). All the military-related studies identified in this table, except Koenigs et al.,54 involved personnel serving in OEF/OIF.

Table 2 contains data points similar to those in Figure 3 except that all levels of TBI severity are included. Of note is that other potentially important parameters also varied considerably (e.g., study size and representativeness, PTSD assessment method, time since trauma exposure). Not taking into account the potential effects of these other variables, the prevalence of TBI/PTSD ranged from 32% to 66% in individuals with military-related TBI.5,22,52–54,81 The prevalence of TBI/PTSD ranged from 14% to 56% in individuals with non-military injuries.56,60,61,69,70,72 As opposed to the studies in which subjects had a history of military-related TBI, all of which reported PTSD prevalence greater than 30%, four of the seven reports involving subjects with non-military injuries reported values less than 30%.60,61,69,70 Whether this is an epidemiologically important difference is not certain, as other study parameters may have simultaneously affected results.

#### Reported prevalence of TBI/PTSD by time since trauma

Similar to trauma type, time since trauma was widely variable across studies and even within studies. Across this group of studies, the potential effect of time since trauma on TBI/PTSD prevalence would best be described in three longitudinal studies enrolling patients with a TBI and assessing for PTSD at different time points post-injury. Unfortunately, no patterns could be discerned. Jones et al. identified PTSD in 32% of patients with TBI history at six weeks post-injury, and in 19% at three months post-injury.61 Greenspan et al. identified PTSD in 11% of patients with TBI history at six months post-injury, and in 16% at twelve months post-injury.58 Bryant and Harvey reported PTSD in 24% of patients with TBI history at six months post-injury, and 22% at two years post-injury.70

#### Reported prevalence of TBI/PTSD by methods of assessment

Studies varied in terms of how a positive screen or diagnosis for PTSD was defined and in how TBI was assessed and defined. Methods of PTSD assessment included structured interviews, self-report instruments, and non-standardized diagnoses by clinicians. Overall, within studies utilizing structured interviews (e.g., CAPS and SCID) to assess PTSD, prevalence of TBI/PTSD ranged from 3% to 70% across study populations.54,59,60,62,63,65,67–72,74,78–80 For studies utilizing self-report instruments (e.g., PCL and IES), prevalence of TBI/PTSD ranged from 5% to 66%.5,22,52,53,55,57,58,64,76,81 One study reported a 10% prevalence of diagnosed TBI/PTSD using the PTSD Inventory; however, it was unclear whether the instrument was used as a self-report instrument or as a structured interview.66 Finally, one study did not articulate how PTSD was defined or diagnosed; this study reported no cases of PTSD among patients with a history of TBI.21 Structured clinical interviews, particularly the CAPS, are considered the gold-standard for PTSD assessment and diagnosis. The studies that used the CAPS to assess PTSD identified prevalence levels of TBI/PTSD ranging from 3% to 38%.59,60,62,72,78,80 Among the studies using the SCID, prevalence ranged from 8% to 44% across entire study populations.54,63,65,67,71,79

Self-report measures, including instruments used for screening, are considered less valid methods for PTSD assessment. Studies that utilized the PTSD Checklist (PCL) to assess for PTSD used different score thresholds to define the presence of PTSD. Studies did not present results in a fashion that would allow for calculation of prevalence at a single common value. The prevalence of TBI/PTSD ranged from 33% to 66% using a cut score of 50 (3 studies),22,53,55 and 35% to 45% using a cut score of 44 (2 studies).52,81 Each of the four studies using the Impact of Events Scale (IES) involved participants with a positive history of TBI. Using a cutoff of 35, Greenspan and colleagues reported a prevalence of 11% six months after injury and a prevalence of 16% twelve months after injury.58 Two studies used a cutoff of 26 and reported prevalence levels of 18% and 34%.64,75 Lastly, Middelboe and colleagues reported that no participants with TBI diagnoses “fulfilled the DSM-III-R criteria for post-traumatic stress disorder,” but 11% had “moderate” or higher scores on the IES.76

Methods of identifying TBI cases also varied widely across studies. Frequently, survey study participants were asked questions varying by study to assess a positive history of TBI.5,21,22,55,63,64,73 Alternatively, participants were recruited from hospitals following treatment for trauma or, specifically, head injury. These patients’ TBI history was obtained from medical records alone or a combination of medical records review supplemented by questionnaire.52,53,56–62,65–70,72,74–76,78,79–81 As a result, systematically examining prevalence of TBI/PTSD by method of TBI assessment was not possible.

## Key Question #2. 2a. What is known about the relative accuracy of diagnostic tests used for assessing mild TBI when comorbid with PTSD? 2b. What is known about the relative accuracy of diagnostic tests used for assessing PTSD when comorbid with mild TBI?

### Summary of Findings

There were no published studies addressing the relative accuracy of diagnostic tests used for assessing mTBI history or current PTSD when one condition co-occurs with the other.

### Secondary Findings

One study compared the relative accuracy of four PTSD assessment tools in a cohort of individuals with a history of severe TBI. A sub-study involving the same population of individuals qualitatively explored reasons for false positive PTSD diagnoses when using a self-report assessment tool versus a structured clinical interview.

### Details of Studies – Secondary Findings

#### Comparison of PTSD assessment tools in individuals with a history of severe TBI

One single-center small study compared four diagnostic measures of PTSD in individuals who had been diagnosed with severe TBI (defined as history of post-traumatic amnesia for more than one day).62 Results varied widely depending on the measures used. Authors administered two self-report measures of PTSD, the IES and the Post-traumatic Diagnostic Scale (PDS), and a structured clinical interview measure for PTSD, the CAPS, to a convenience sample of 34 civilians whose severe TBI event had occurred at least three months prior to the study (Table 3). Four sets of criteria were used to define cases of PTSD: 1) IES scores > 25; 2) fulfillment of PDS criteria B-F; 3) fulfillment of CAPS criteria B-F; and 4) fulfillment of CAPS criteria B-F plus a clinician’s judgment that the endorsed symptoms were valid and indeed related to trauma. The latter two criteria were referred to as “CAPS-without clinical judgment” and “CAPS-with clinical judgment,” respectively. Participants were primarily male (88%), were aged 20–60 years (mean=34; SD=11), and had 10–20 years of formal education (mean=12; SD=2). The sources of injury were motor vehicle crashes (47%), falls (32%), assaults (18%), and sports activities (3%).

Table 3 Secondary findings for Key Question 2: Assessment of PTSD in individuals with severe TBI

Study/Country | Study design and population | n | Characteristics of participants | Traumatic brain injury definition/measure | Post-traumatic stress disorder assessment | % of subjects fulfilling criteria for PTSD
Sumpter 2005;^62^ Sumpter 2006^35^ United Kingdom | Cross-sectional Subjects recruited from community outpatient and rehabilitation services, and volunteer organizations | n=34; all TBI | Data for all study subjects Trauma etiology: MVC 47%; fall 32%; assault 18%; sports injury 3% TBI severity: severe 100% Time of assessment or since trauma: 6 years (0.6–34) Mean age (range): 40 (20–60) Women: 12% Race: NR Education: NR Pain: NR Mental health disorders other than PTSD: NR | Not reported, subjects with severe TBI history recruited from community outpatient and rehabilitation services and voluntary organizations. | Compared 4 assessment tools: 1) Post-traumatic Diagnostic Scale (PDS), based on DSM-IV criteria, criteria B-F fulfilled 2) Impact of Event Scale questionnaire (IES), total score > 25 = “case” 3) Clinician-Administered PTSD Scale (CAPS), without clinical judgment, criteria B-F fulfilled 4) CAPS, with clinical judgment, criteria B-F fulfilled | 1) PDS: 59% (n=20) 2) IES: 44% (n=15) 3) CAPS w/o clinical judgment: 18% (n=6) 4) CAPS with clinical judgment: 3% (n=1)

Fulfillment of CAPS-with clinical judgment was considered the gold-standard PTSD diagnostic tool in this study. Only one individual (3%) met criteria for PTSD based on this assessment tool. Six individuals (18%) met criteria based on CAPS-without clinical judgment, 15 (44%) met criteria based on the IES, and 20 (59%) met criteria based on the PDS. Both self-report questionnaires (IES and PDS) identified significantly more (p<0.05) false positive PTSD cases than CAPS-without clinical judgment. There were no false negative cases identified by the IES or PDS; all cases identified by CAPS-without clinical judgment were also identified by these self-report questionnaires. Therefore, based on the definitions used by these authors, this study supports the use of the IES and PDS self-report questionnaires as screening tools for PTSD among individuals with severe TBI. However, structured clinical interviews were deemed the most appropriate diagnostic tool for diagnosis of PTSD after severe TBI. There was indication that individuals may have mistaken their TBI-related symptoms for PTSD symptoms on the self-report questionnaires, with these discrepancies becoming clear only during the process of structured clinical interview. Clinical judgment thus provided the opportunity for differential diagnosis of PTSD versus symptoms of severe TBI based on the context of the symptoms as well as potentially confounding factors.

#### Potential reasons for false positive PTSD diagnoses in individuals with a history of severe TBI

One qualitative study was conducted by the same authors as above and explored reasons for false positive PTSD diagnoses when using a self-report assessment tool (PDS) as compared to a structured clinical interview (CAPS) as the “gold-standard” assessment method.35 The study population consisted of the same 34 civilians with a severe TBI history; however, the sole individual diagnosed with PTSD using the CAPS-with clinical judgment was excluded so as to examine PTSD symptoms that were reported by individuals without PTSD.

Self-reported and clinician-rated PTSD symptoms (PDS versus CAPS) were compared by DSM-IV PTSD symptoms clusters: re-experiencing, avoidance, and hyperarousal. Based on the PDS, 91% of participants reported two or more hyperarousal symptoms, 78% reported three or more avoidance symptoms, and 67% reported at least one re-experiencing symptom. Only one PTSD symptom (insomnia) was reported in more than 20% of participants when using the CAPS. Using a standardized interview prompt to explore the identified discrepancies, investigators found that cognitive impairments, misunderstanding of self-report items, and true symptoms overlap seemed to lead to endorsement of PTSD symptoms on the PDS. For example, individuals with loss of memory for their traumatic event confused “curiosity” about their event for “re-experiencing” the event. While symptoms may have been reported as “intrusive,” they were not found to be accompanied by fear or emotional distress. Additionally, while participants frequently endorsed “having upsetting thoughts,” these thoughts were often associated with the effects of the severe TBI and not with the trauma itself. Similarly, avoidance-related questions (e.g., loss of interest, detachment, or reduction in affect) were frequently endorsed in relation to functional difficulties associated with the severe TBI rather than the traumatic event. Endorsement of hyperarousal symptoms often had to do with individuals having to cope with cognitive and physical impairments and fear of re-injury. In all, this study highlights the overlap and potential confusion around assessment of symptoms of PTSD and symptoms related to a TBI.

## Key Question #3. 3a. Are there psychosocial or pharmacological therapies used for treatment of mTBI and PTSD simultaneously? 3b. Are therapies for treatment of mTBI effective when mTBI is comorbid with PTSD? Is there evidence of harms? 3c. Are therapies for treatment of PTSD effective when PTSD is comorbid with mTBI? Is there evidence of harms?

### Summary of Findings

- 3A: We found no randomized or non-randomized controlled clinical trials, systematic reviews, cohort studies, case control studies, or cross-sectional studies that discussed psychosocial or pharmacological therapies designed to simultaneously treat symtpoms of mTBI and PTSD.
- 3B: We found no randomized or non-randomized controlled clinical trials, systematic reviews, cohort studies, case control studies, or cross-sectional studies that examined the effectivess of treatments for mTBI symptoms when patients had PTSD.
- 3C: We found no randomized or non-randomized controlled clinical trials, systematic reviews, cohort studies, case control studies, or cross-sectional studies that examined the effectivess of treatments for PTSD when patients had a history of mTBI.

### Secondary Findings

One small, single-center, good-quality randomized controlled trial examined the efficacy of a cognitive-behavioral treatment for individuals with acute stress disorder (ASD) and a history of mTBI. The study found that patients who received cognitive-behavioral therapy developed PTSD at a lower rate than those who received supportive therapy.

Two case reports discussed treatment approaches that utilized empirically supported therapies to treat individuals with mTBI history and current PTSD.

### Details of Studies – Secondary Findings

#### Treatment of mTBI and Acute Stress Disorder

One small, good quality study examined the comparative efficacy of cognitive-behavior therapy (CBT) and supportive therapy in reducing symptoms and preventing the development of PTSD in 24 civilians with history of mTBI and current acute stress disorder (ASD; Table 4).82 ASD is a post-traumatic stress reaction that occurs within the first month post-trauma. The symptoms are similar to PTSD, with the exception that individuals with ASD must also experience symptoms of dissociation. Previous research has shown that approximately 80% of people with ASD go on to develop PTSD.83

Table 4 Secondary findings for Key Question 3: Treatment of mTBI/PTSD

Study/Country/Study design | # Subjects; % Dropout/Lost to follow-up | Subjects | Method of assessment | Treatment | Duration of therapy | Treatment outcomes | Study quality
Bryant 2003^82^ Australia Randomized Controlled Trial (RCT) | n=24 | Mean age (range): 31 (18 – 60) Women: 67% Race: NR Trauma etiology: motor vehicle crash (MVC) or non-sexual assault Pain: NR Other mental health conditions: NR | TBI: Glasgow Coma Scale PTSD: Impact of Event Scale (IES) and Clinician Administered PTSD Scale (CAPS) | 1. Cognitive Behavior Therapy (CBT) Group (n=12) 2. Supportive Counseling (SC) Group (n=12) | 6 mos | [underlined: Mean CAPS scores (SD)] Baseline CBT: 65.42 (10.60) SC: 62.42 (14.58) Frequency subscale a. Post-treatment CBT: 13.50 (10.24) SC: 23.83 (15.30); p=0.002 b. 6 mos follow-up CBT: 16.83 (13.04) SC: 25.25 (16.21); p=0.03Intensity subscale a. Post-treatment CBT: 12.00 (9.71) SC: 21.33 (12.49); p=0.003 b. 6 mos follow-up CBT: 14.62 (9.12) SC: 24.50 (13.13); p=0.02[underlined: Subjects meeting PTSD criteria:] a. Post-treatment CBT: 8% (n=1) SC: 58% (n=7); p<0.05 b. 6 mos follow-up CBT: 17% (n=2) SC: 58% (n=7); p<0.05 | Good
Batten 2008^84^ U.S. Case Report | 1 | 24 year old, Caucasian male Trauma etiology: Combat Pain: joint pain and headaches Other mental health conditions: depression, alcohol abuse, marijuana abuse | TBI: Clinic diagnosis, criteria unknown PTSD: Clinician Administered PTSD Scale (CAPS) & PTSD Checklist (PCL) | Cognitive processing therapy; two sessions outlining behavioral activation for depression & sleep hygiene; one session on decreasing substance abuse; addressed memory compensation strategies with polytrauma team | 19 individual therapy sessions | Lost PTSD diagnosis, although still had significant symptoms; decreased symptoms of depression; decreased alcohol use; marijuana abstinence | Poor
McGrath 1997^85^ England Case Report | 1 | 33 year old male Race: NR Trauma etiology: MVC Pain: Ear pain and headaches Other mental health conditions: NR | TBI: Head injury with PTA of 40 minutes PTSD: Clinical interview used to determine DSM-IV criteria | Progressive muscle relaxation; anger management; cognitive restructuring; graded in vivo exposure; response prevention for checking behaviors; compensatory cognitive strategies; supportive therapy | NR | Slight decrease in anxiety symptoms; decrease in anger; decrease in symptoms of depression; no change in subjective cognitive symptoms, but improved work functioning | Poor

This randomized controlled trial enrolled men and women who had experienced either a motor vehicle crash or nonsexual assault within the preceding two weeks. In order to be eligible, patients must have met criteria for ASD, as determined by the Acute Stress Disorder Interview, and mTBI, which was defined as post-traumatic amnesia of less than 24 hours and a Glasgow Coma Scale score of 13–15. Those randomized to CBT received five weekly 90-minute sessions that included psychoeducation, progressive muscle relaxation, imaginal exposure to the traumatic event, cognitive restructuring, and in vivo exposure to avoided stimuli. Patients in the supportive counseling condition also received five weekly 90-minute sessions, comprised of psychoeducation and problem-solving skills. There was no mention of modificiations made to the therapy protocols due to potential cognitive impairments in the study participants.

Immediately post-treatment, PTSD was less prevalent in the CBT group (8%; n=1) than the supportive therapy group (58%; n=7). At the six-month follow-up, 17% (n=2) of the CBT group and 58% (n=7) of the supportive therapy group met criteria for PTSD. Further, at post-treatment and six-month follow-up, patients in the CBT condition experienced large, significant decreases in PTSD symptomology (as measured by both the IES and CAPS). Both groups experienced a moderate decrease in depressive symptoms at post-treatment and a small decrease at six-month follow-up, but there was not a statistically significant difference between the groups. The authors concluded that CBT is effective in reducing symptoms and preventing onset of PTSD in patients with ASD and mTBI history.

#### Case studies reporting on the treatment of patients with mTBI/PTSD

Two case reports (one involving a U.S. military patient) presented information regarding the treatment of mTBI symptoms and PTSD in individual patients (Table 4).84,85 In both case reports, the therapist used cognitive-behavioral techniques to treat the symptoms of PTSD (cognitive processing therapy; exposure and cognitive restructuring) with few modifications. To manage mTBI-related symptoms, the therapists encouraged the patients to use compensatory strategies (e.g., using personal digital assistants, scheduling cognitive breaks). Both reports highlighted the range of problems experienced by the individuals they were treating (e.g., anger, depression, substance abuse) and advocated for an idiographic, integrative approach. These case studies reported a decrease in symptoms of anxiety and depression; however, significant residual symptoms remained.

## Literature Review KQ 1–3 - Limitations

The existing literature has several limitations. The quality of identified studies was generally fair and external validity was generally poor. Few prevalence studies were actually population-based. Most were small and conducted in a single medical or research center. Authors frequently only recruited individuals who had been hospitalized or received medical attention specifically for their trauma. No large studies representative of the entire OEF/OIF veteran population have been conducted using currently implemented screening and diagnostic tools. Therefore, the applicability of the current literature to existing populations of interest, screened and diagnosed with currently utilized tools, is not known. By extension, the true prevalence of TBI/PTSD, particularly mTBI/PTSD, is not known. Reported findings from most studies likely overestimate the prevalence of TBI/PTSD, especially mTBI/PTSD, in the populations of interest. For example, civilian individuals recruited from emergency departments likely represent more severe, more symptomatic cases of TBI (and PTSD) than individuals who experience a TBI for which they do not seek medical attention. Assessment instruments, ascertainment methods, timing, and diagnostic criteria used to identify TBI and PTSD cases varied widely. Different methods and thresholds to define disease and injury can have profound impact on the prevalence, severity, natural history and response to treatment of a condition. This may be particularly relevant where individual responses may be affected by the potential for compensation. Study populations were heterogeneous and results were rarely reported according to key clinical characteristics of interest (e.g., age, gender, race, socioeconomic status, trauma etiology or time, presence of pain or mental health disorders other than PTSD) that may have an impact on prevalence estimates. We attempted to minimize publication bias by using broad search terms and multiple databases, and by seeking input from our Technical Advisory Panel members and external peer reviewers (including consensus panel members). We included the large RAND study,5 even though it may not technically meet definitions for peer-reviewed publications.

## ACTIVE RESEARCH

### Summary of Findings

Although there are a number of ongoing, active research studies that include patients with TBI/PTSD, few will specifically address the key questions identified for this report.

### Details of Findings

The ongoing studies, sorted by key question, are summarized in Appendix E, Tables 1–3. We identified seven studies that will provide information about the prevalence of TBI/PTSD (Table 1). Six of the studies include OEF and/or OIF soldiers or veterans. Sample sizes vary widely; the largest study intends to assess TBI history and PTSD in up to 60,000 veterans. The methods of assessment of TBI history and PTSD vary and include chart review, self report, symptom checklists, and structured diagnostic interviews.

We identified eight studies that will provide information related to the assessment of mTBI/PTSD (Table 2). Three of the studies will also address key question #1 and are included in Appendix E, Table 1. All but one of the studies include military personnel, with reported sample sizes ranging from 120 to 850. The methods of assessment are largely similar to those reported in Table 1, although magnetic resonance imaging, sleep studies, neuroendocrine measures, and a smell test are also being used.

Six studies were identified that examine treatments for symptoms of mTBI/PTSD. Five of the studies include OEF/OIF veterans or their family members; the remaining study will likely include veterans. Reported sample sizes range from 6 to 300. Treatments to be evaluated include psychotherapy, psychiatric and sleep medications, relaxation therapy, sleep education, support teams, and hyperbaric oxygen therapy. One of the studies is a randomized, controlled trial.

## ACTIVE RESEARCH - LIMITATIONS

Our reporting of active research is based solely on responses obtained from individuals who received our request for information and chose to respond. No follow-up contact was made with non-responders. Thus, there may be other ongoing studies pertinent to our key questions that were not identified by this process. Most ongoing studies we identified are not enrolling broad-based populations of individuals to estimate population prevalence of TBI/PTSD (especially mTBI/PTSD). We did not identify any studies that attempt to compare the diagnostic accuracy of different assessment tools for identification of TBI history or current PTSD when the conditions co-occur (especially for individuals likely to have mTBI/PTSD). We identified only one ongoing randomized and controlled treatment trial. Future research needs to incorporate these items to ensure that the key questions covered in this review can be addressed.

The studies listed in Appendix E all include at least some patients with TBI/PTSD. Given the ongoing nature of the studies, it was not always possible to identify the exact proportion of patients who would have TBI/PTSD or the severity of the TBI experienced by the patients.