# REFERENCE LIST

1 Centers for Disease Control and Prevention. Traumatic brain injury in the United States: A report to Congress. Atlanta, GA. Centers for Disease Control and Prevention. 1999.
2 Institute of Medicine (IOM). Gulf war and health, Volume 7: Long-term consequences of traumatic brain injury. Washington, DC. The National Academies Press. 2009.
3 Warden D. Military TBI during the Iraq and Afghanistan wars. J Head Trauma Rehabil. 2006;21(5):398-402. [pmid: 16983225].
4 Okie S. Traumatic brain injury in the war zone. N Engl J Med. 2005;352(20):2043-2047. [pmid: 15901856].
5 Tanielian T, Jaycox LH, editors. Invisible wounds of war: Psychological and cognitive injuries, their consequences, and services to assist recovery. Santa Monica, CA. Rand Corporation. 2008. Available at: http://www.rand.org/pubs/monographs/MG720/.
6 Management of Concussion/mTBI Working Group. VA/DoD clinical practice guideline for management of concussion/mild traumatic brain injury. Washington DC. Department of Veterans Affairs and Department of Defense. 2009.
7 Gordon WA, Zafonte R, Cicerone K, Cantor J, Brown M, Lombard L, et al. Traumatic brain injury rehabilitation: state of the science. Am J Phys Med Rehabil. 2006;85(4):343-382. [pmid: 16554685].
8 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4th ed. text revision ed. Washington, DC. American Psychiatric Association. 2000.
9 Kessler RC, Sonnega A, Bromet E, Hughes M, Nelson CB. Posttraumatic stress disorder in the National Comorbidity Survey. Arch Gen Psychiatry. 1995;52(12):1048-1060. [pmid: 7492257].
10 Resnick HS, Kilpatrick DG, Dansky BS, Saunders BE, Best CL. Prevalence of civilian trauma and posttraumatic stress disorder in a representative national sample of women. J Consult Clin Psychol. 1993;61(6):984-991. [pmid: 8113499].
11 Dohrenwend BP, Turner JB, Turse NA, Adams BG, Koenen KC, Marshall R. The psychological risks of Vietnam for U.S. veterans: A revisit with new data and methods. Science. 2006;313(5789):979-982. [pmid: 16917066].
12 Hoge CW, Terhakopian A, Castro CA, Messer SC, Engel CC. Association of posttraumatic stress disorder with somatic symptoms, health care visits, and absenteeism among Iraq war veterans. Am J Psychiatry. 2007;164(1):150-153. [pmid: 17202557].
13 Milliken CS, Auchterlonie JL, Hoge CW. Longitudinal assessment of mental health problems among active and reserve component soldiers returning from the Iraq War. JAMA. 2007;298(18):2141-2148. [pmid: 18000197].
14 Boscarino JA. Diseases among men 20 years after exposure to severe stress: Implications for clinical research and medical care. Psychosom Med. 1997;59(6):605-614. [pmid: 9407579].
15 Boscarino JA, Chang J. Electrocardiogram abnormalities among men with stress-related psychiatric disorders: Implications for coronary heart disease and clinical research. Ann Behav Med. 1999;21(3):227-234. [pmid: 10626030].
16 Kessler RC. Posttraumatic stress disorder: The burden to the individual and to society. J Clin Psychiatry. 2000;61(S5):4-12. [pmid: 10761674].
17 Savoca E, Rosenheck R. The civilian labor market experiences of Vietnam-era veterans: The influence of psychiatric disorders. J Ment Health Policy Econ. 2000;3(4):199-207. [pmid: 11967456].
18 Schnurr PP, Hayes AF, Lunney CA, McFall M, Uddo M. Longitudinal analysis of the relationship between symptoms and quality of life in veterans treated for posttraumatic stress disorder. J Consult Clin Psychol. 2006;74(4):707-713. [pmid: 16881778].
19 Polusny MA. Final Report for VA HSR&D Project RRP 08-252: Mild TBI/PTSD comorbidity and post-deployment outcomes in National Guard Soldiers. 2009. Abstract available at: http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141698843.
20 Bryant RA, Hopwood S. Commentary on “Trauma to the Psyche and Soma. Cogn Behav Pract. 2006;13(1):17-23.
21 Sbordone RJ, Liter JC. Mild traumatic brain injury does not produce post-traumatic stress disorder. Brain Inj. 1995;9(4):405-412. [pmid: 7640686].
22 Hoge CW, McGurk D, Thomas JL, Cox AL, Engel CC, Castro CA. Mild traumatic brain injury in U.S. Soldiers returning from Iraq. N Engl J Med. 2008;358(5):453-463. [pmid: 18234750].
23 Hoge CW, Goldberg HM, Castro CA. Care of war veterans with mild traumatic brain injury--flawed perspectives. N Engl J Med. 2009;360(16):1588-1591. [pmid: 19369664].
24 Institute of Medicine. Gulf war and health: Volume 7. Long-term consequences of traumatic brain injury. December. 4. 2008. Available at: http://www.iom.edu/CMS/4683/60519.aspx.
25 Kennedy JE, Jaffee MS, Leskin GA, Stokes JW, Leal FO, Fitzpatrick PJ. Posttraumatic stress disorder and posttraumatic stress disorder-like symptoms and mild traumatic brain injury. J Rehabil Res Dev. 2007;44(7):895-920. [pmid: 18075948].
26 King NS. PTSD and traumatic brain injury: Folklore and fact?. Brain Inj. 2008;22(1):1-5. [pmid: 18183503].
27 Rogers JM, Read CA. Psychiatric comorbidity following traumatic brain injury. Brain Inj. 2007;21(13–14):1321-1333. [pmid: 18066935].
28 Correspondence. Care of war veterans with mild traumatic brain injury. N Engl J Med. 2009;361(15):536-538.
29 McMillan TM. Errors in diagnosing post-traumatic stress disorder after traumatic brain injury. Brain Inj. 2001;15(1):39-46. [pmid: 11201313].
30 Kim E, Lauterbach EC, Reeve A, Arciniegas DB, Coburn KL, Mendez MF, et al. Neuropsychiatric complications of traumatic brain injury: a critical review of the literature (A report by the ANPA Committee on Research). J Neuropsychiatry Clin Neurosci. 2007;19(2):106-127. [pmid: 17431056].
31 Moore EL, Terryberry-Spohr L, Hope DA. Mild traumatic brain injury and anxiety sequelae: A review of the literature. Brain Inj. 2006;20(2):117-132. [pmid: 16421060].
32 O’Donnell ML, Creamer M, Bryant RA, Schnyder U, Shalev A. Posttraumatic disorders following injury: An empirical and methodological review. Clin Psychol Rev. 2003;23(4):587-603. [pmid: 12788111].
33 Hiott DW, Labbate L. Anxiety disorders associated with traumatic brain injuries. NeuroRehabilitation. 2002;17(4):345-355. [pmid: 12547982].
34 Ohry A, Rattok J, Solomon Z. Post-traumatic stress disorder in brain injury patients. Brain Inj. 1996;10(9):687-695. [pmid: 8853871].
35 Sumpter RE, McMillan TM. Errors in self-report of post-traumatic stress disorder after severe traumatic brain injury. Brain Inj. 2006;20(1):93-99. [pmid: 16403704].
36 Cahill SP, Rothbaum BO, Resick PS, Follette VM. Cognitive-behavioral therapy for adults. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective Treatments for PTSD: Practice Guidelines for the International Society for Traumatic Stress Studies. New York. Guilford Press. 2009:139-222.
37 Monson CM, Schnurr PP, Resick PS, Friedman MJ, Young-Xu Y, Stevens SP. Cognitive processing therapy for veterans with military-related posttraumatic stress disorder. J Consult Clin Psychol. 2006;74(5):898-907. [pmid: 17032094].
38 Schnurr PP, Friedman MJ, Engel CC, Foa EB, Shea MT, Chow BK, et al. Cognitive behavioral therapy for posttraumatic stress disorder in women: A randomized controlled trial. JAMA-J Am Med Assoc. 2007;297(8):820-830.
39 Rauch SA, Defever E, Favorite T, Duroe A, Garrity C, Martis B, et al. Prolonged exposure for PTSD in a Veterans Health Administration PTSD clinic. J Trauma Stress. 2009;22(1):60-64. [pmid: 19145643].
40 Paniak C, Toller-Lobe G, Durand A, Nagy J. A randomized trial of two treatments for mild traumatic brain injury. Brain Inj. 1998;12(12):1011-1023. [pmid: 9876861].
41 Paniak C, Toller-Lobe G, Reynolds S, Melnyk A, Nagy J. A randomized trial of two treatments for mild traumatic brain injury: 1 year follow-up. Brain Inj. 2000;14(3):219-226. [pmid: 10759039].
42 Nampiaparampil DE. Prevalence of chronic pain after traumatic brain injury: A systematic review. JAMA-J Am Med Assoc. 2008;300(6):711-719.
43 Carroll LJ, Cassidy JD, Holm L, Kraus J, Coronado VG. Methodological issues and research recommendations for mild traumatic brain injury: The WHO Collaborating Centre Task Force on Mild Traumatic Brain Injury. J Rehabil Med. 2004;43S:113-125. [pmid: 15083875].
44 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. Washington, DC. American Psychiatric Association. 1980.
45 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. revised ed. Washington, DC. American Psychiatric Association. 1987.
46 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4th ed. Washington, DC. American Psychiatric Association. 1994.
47 Bossuyt PM, Reitsma JB, Bruns DE, Gatsonis CA, Glasziou PP, Irwig LM, et al. The STARD statement for reporting studies of diagnostic accuracy: Explanation and elaboration. Ann Intern Med. 2003;138(1):W1-12. [pmid: 12513067].
48 Leeflang MM, Deeks JJ, Gatsonis C, Bossuyt PM. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149(12):889-897. [pmid: 19075208].
49 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
50 GRADE Working Group. Grading quality of evidence and strength of recommendations. Brit Med J. 2004;328(7454):1490. [pmid: 15205295].
51 Dobscha SK, Campbell R, Morasco BJ, Freeman M, Helfand M. Pain in patients with polytrauma: A systematic review. Washington, DC. Department of Veterans Affairs. 2008. Available at: http://www.hsrd.research.va.gov/publications/esp/Pain-in-Polytrauma-2008.pdf.
52 Gaylord KM, Cooper DB, Mercado JM, Kennedy JE, Yoder LH, Holcomb JB. Incidence of posttraumatic stress disorder and mild traumatic brain injury in burned service members: Preliminary report. J Trauma. 2008;64(2 Suppl):S200-205. [pmid: 18376167].
53 Ruff RL, Ruff SS, Wang XF. Headaches among Operation Iraqi Freedom/Operation Enduring Freedom veterans with mild traumatic brain injury associated with exposures to explosions. J Rehabil Res Dev. 2008;45(7):941-952. [pmid: 19165684].
54 Koenigs M, Huey ED, Raymont V, Cheon B, Solomon J, Wassermann EM, et al. Focal brain damage protects against post-traumatic stress disorder in combat veterans. Nat Neurosci. 2008;11(2):232-237. [pmid: 18157125].
55 Schneiderman AI, Braver ER, Kang HK. Understanding sequelae of injury mechanisms and mild traumatic brain injury incurred during the conflicts in Iraq and Afghanistan: Persistent postconcussive symptoms and posttraumatic stress disorder. Am J Epidemiol. 2008;167(12):1446-1452. [pmid: 18424429].
56 Schwartz I, Tsenter J, Shochina M, Shiri S, Kedary M, Katz-Leurer M, et al. Rehabilitation outcomes of terror victims with multiple traumas. Arch Phys Med Rehabil. 2007;88(4):440-448. [pmid: 17398244].
57 Bombardier CH, Fann JR, Temkin N, Esselman PC, Pelzer E, Keough M, et al. Posttraumatic stress disorder symptoms during the first six months after traumatic brain injury. J Neuropsychiatry Clin Neurosci. 2006;18(4):501-508. [pmid: 17135375].
58 Greenspan AI, Stringer AY, Phillips VL, Hammond FM, Goldstein FC. Symptoms of post-traumatic stress: Intrusion and avoidance 6 and 12 months after TBI. Brain Inj. 2006;20(7):733-742. [pmid: 16809206].
59 Creamer M, O’Donnell ML, Pattison P. Amnesia, traumatic brain injury, and posttraumatic stress disorder: A methodological inquiry. Behav Res Ther. 2005;43(10):1383-1389. [pmid: 16086988].
60 Gil S, Caspi Y, Ben Ari IZ, Koren D, Klein E. Does memory of a traumatic event increase the risk for posttraumatic stress disorder in patients with traumatic brain injury? A prospective study. Am J Psychiatry. 2005;162(5):963-969. [pmid: 15863799].
61 Jones C, Harvey AG, Brewin CR. Traumatic brain injury, dissociation, and posttraumatic stress disorder in road traffic accident survivors. J Trauma Stress. 2005;18(3):181-191. [pmid: 16281212].
62 Sumpter RE, McMillan TM. Misdiagnosis of post-traumatic stress disorder following severe traumatic brain injury. Br J Psychiatry. 2005;186:423-426. [pmid: 15863748].
63 Ashman TA, Spielman LA, Hibbard MR, Silver JM, Chandna T, Gordon WA. Psychiatric challenges in the first 6 years after traumatic brain injury: Cross-sequential analyses of Axis I disorders. Arch Phys Med Rehabil. 2004;85(4 Suppl 2):S36-42. [pmid: 15083420].
64 Williams WH, Evans JJ, Wilson BA, Needham P. Brief report: Prevalence of post-traumatic stress disorder symptoms after severe traumatic brain injury in a representative community sample. Brain Inj. 2002;16(8):673-679. [pmid: 12167192].
65 Berthier ML, Kulisevsky JJ, Gironell A, Lopez OL. Obsessivecompulsive disorder and traumatic brain injury: Behavioral, cognitive, and neuroimaging findings. Neuropsychiatry Neuropsychol Behav Neurol. 2001;14(1):23-31. [pmid: 11234906].
66 Hoofien D, Gilboa A, Vakil E, Donovick PJ. Traumatic brain injury (TBI) 10–20 years later: A comprehensive outcome study of psychiatric symptomatology, cognitive abilities and psychosocial functioning. Brain Inj. 2001;15(3):189-209. [pmid: 11260769].
67 McCauley SR, Boake C, Levin HS, Contant CF, Song JX. Postconcussional disorder following mild to moderate traumatic brain injury: Anxiety, depression, and social support as risk factors and comorbidities. J Clin Exp Neuropsychol. 2001;23(6):792-808. [pmid: 11910545].
68 Bryant RA, Harvey AG. Postconcussive symptoms and posttraumatic stress disorder after mild traumatic brain injury. J Nerv Ment Dis. 1999;187(5):302-305. [pmid: 10348085].
69 Bryant RA, Harvey AG. The influence of traumatic brain injury on acute stress disorder and post-traumatic stress disorder following motor vehicle accidents. Brain Inj. 1999;13(1):15-22. [pmid: 9972438].
70 Bryant RA, Harvey AG. Relationship between acute stress disorder and posttraumatic stress disorder following mild traumatic brain injury. Am J Psychiatry. 1998;155(5):625-629. [pmid: 9585713].
71 Hibbard MR, Uysal S, Kepler K, Bogdany J, Silver J. Axis I psychopathology in individuals with traumatic brain injury. J Head Trauma Rehabilil. 1998;13(4):24-39.
72 Hickling EJ, Gillen R, Blanchard EB, Buckley T, Taylor A. Traumatic brain injury and posttraumatic stress disorder: A preliminary investigation of neuropsychological test results in PTSD secondary to motor vehicle accidents. Brain Inj. 1998;12(4):265-274. [pmid: 9562909].
73 Trudeau DL, Anderson J, Hansen LM, Shagalov DN, Schmoller J, Nugent S, et al. Findings of mild traumatic brain injury in combat veterans with PTSD and a history of blast concussion. J Neuropsychiatry Clin Neurosci. 1998;10(3):308-313. [pmid: 9706538].
74 Warden DL, Labbate LA, Salazar AM, Nelson R, Sheley E, Staudenmeier J, et al. Posttraumatic stress disorder in patients with traumatic brain injury and amnesia for the event?. J Neuropsychiatry Clin Neurosci. 1997;9(1):18-22. [pmid: 9017524].
75 Powell JH, Al Adawi S, Morgan J, Greenwood RJ. Motivational deficits after brain injury: Effects of bromocriptine in 11 patients. J Neurol Neurosurg psychiatry. 1996;60(4):416-421. [pmid: 8774407].
76 Middelboe T, Andersen HS, Birket-Smith M, Friis ML. Minor head injury: Impact on general health after 1 year. A prospective follow-up study. Acta Neurol Scand. 1992;85(1):5-9. [pmid: 1546534].
77 Powell TJ, Collin C, Sutton K. A follow-up study of patients hospitalized after minor head injury. Disabil Rehabil. 1996;18(5):231-237. [pmid: 8743300].
78 Turnbull SJ, Campbell EA, Swann IJ. Post-traumatic stress disorder symptoms following a head injury: Does amnesia for the event influence the development of symptoms?. Brain Inj. 2001;15(9):775-785. [pmid: 11516346].
79 Brenner LA, Ladley-O’Brien SE, Harwood JEF, Filley CM, Kelly JP, Homaifar BY, et al. An exploratory study of neuroimaging, neurologic, and neuropsychological findings in veterans with traumatic brain injury and/or posttraumatic stress disorder. Mil Med. 2009;174(4):347-352. [pmid: 19485102].
80 Chalton LD, McMillan TM. Can ‘partial’ PTSD explain differences in diagnosis of PTSD by questionnaire self-report and interview after head injury?. Brain Inj. 2009;23(2):77-82. [pmid: 19191086].
81 Mora AG, Ritenour AE, Wade CE, Holcomb JB, Blackbourne LH, Gaylord KM. Posttraumatic stress disorder in combat casualties with burns sustaining primary blast and concussive injuries. J Trauma. 2009;66:S178-S185. [pmid: 19359963].
82 Bryant RA, Moulds M, Guthrie R, Nixon RD. Treating acute stress disorder following mild traumatic brain injury. Am J Psychiatry. 2003;160(3):585-587. [pmid: 12611847].
83 Harvey AG, Bryant RA. Acute stress disorder after mild traumatic brain injury. J Nerv Ment Dis. 1998;186(6):333-337. [pmid: 9653416].
84 Batten SV, Pollack SJ. Integrative outpatient treatment for returning service members. J Clin Psychol. 2008;64(8):928-939. [pmid: 18561182].
85 McGrath J. Cognitive impairment associated with post-traumatic stress disorder and minor head injury: A case report. Neuropsych Rehabil. 1997;7(3):231-239.
86 Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J. The development of QUA-DAS: A tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
87 von Elm E, Altman DG, Egger M, Pocock SJ, Gotzsche PC, Vandenbroucke JP. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: Guidelines for reporting observational studies. Ann Intern Med. 2007;147(8):573-577. [pmid: 17938396].
88 Schwartz I, Tuchner M, Tsenter J, Shochina M, Shoshan Y, Katz-Leurer M, Meiner Z. Cognitive and functional outcomes of terror victims who suffered from traumatic brain injury. Brain Inj. 2008;22(3):255-263. [pmid: 18297597].
89 Bryant RA, Marosszeky JE, Crooks J, Gurka JA. Posttraumatic stress disorder after severe traumatic brain injury. Am J Psychiatry. 2000;157(4):629-631. [pmid: 10739426].
90 Bryant RA, Marosszeky JE, Crooks J, Baguley I, Gurka J. Coping style and post-traumatic stress disorder following severe traumatic brain injury. Brain Inj. 2000;14(2):175-180. [pmid: 10695572].
91 Bryant RA, Marosszeky JE, Crooks J, Baguley IJ, Gurka JA. Posttraumatic stress disorder and psychosocial functioning after severe traumatic brain injury. J Nerv Ment Dis. 2001;189(2):109-113. [pmid: 11225683].
92 Bryant RA, Marosszeky JE, Crooks J, Gurka JA. Elevated resting heart rate as a predictor of posttraumatic stress disorder after severe traumatic brain injury. Psychosom Med. 2004;66(5):760-761. [pmid: 15385703].
93 Harvey AG, Bryant RA. Two-year prospective evaluation of the relationship between acute stress disorder and posttraumatic stress disorder following mild traumatic brain injury. Am J Psychiatry. 2000;157(4):626-628. [pmid: 10739425].