# INTRODUCTION

Traumatic brain injury (TBI) has been defined as trauma to the head that results in a decreased level of consciousness, amnesia, other neurologic or neuropsychologic abnormalities, skull fractures, intracranial lesions, or death.1 TBI can be caused by penetrating trauma or by blunt force, including acceleration/deceleration forces that cause the brain to collide with the skull.1 Blunt force TBI is typically classified by level of severity, most commonly differentiated as mild, moderate, or severe. The vast majority of civilian patients that are hospitalized for TBI are diagnosed with mild TBI (mTBI).2 While a similar ratio specific to soldiers or veterans is not readily available, mTBI is also prevalent in this population.3 Personnel engaged in the current military operations, Operation Enduring Freedom and Operation Iraqi Freedom (OEF/OIF), are sustaining mTBI at unprecedented rates.4 One commonly referenced report estimated that nearly 20%, or 300,000, OEF/OIF veterans had sustained a TBI during deployment,5 many of these being mTBI. There has been much political and media interest in the rates of mTBI associated with the current conflicts. While most of those who sustain mTBI do not experience ongoing symptoms, a minority of individuals will experience some psychosocial, mental, and/or physical health problems.6,7 Thus, there is major concern across veteran healthcare providers, particularly the U.S. Department of Veterans Affairs (VA) and Department of Defense (DoD), regarding the identification and care of mTBI.

Post-traumatic stress disorder (PTSD) is a highly prevalent and pernicious mental health problem with significant costs to the individual and society. It is an anxiety disorder characterized by avoidance behaviors, physiological hyperarousal, and re-experiencing symptoms following exposure to a traumatic event.8 Population-based epidemiologic studies have shown that nearly 56% of people will experience a psychologically traumatic event, and between 8–12% of individuals will meet criteria for PTSD during their lifetimes.9,10 United States (U.S.) military veterans’ risk of developing PTSD is higher than the risk in the general U.S. population. The lifetime prevalence of PTSD among Vietnam veterans is estimated to be 19%.11 Similar patterns are being observed among OEF/OIF soldiers and veterans. A study by Hoge and colleagues found that exposure to traumatic events was extremely high among OIF soldiers and Marines, with 93% to 97% having been shot at and approximately 95% having seen human remains.12 Screening data from OIF soldiers suggest that approximately 17% of active duty soldiers and 25% of reserve soldiers may meet criteria for PTSD three to six months post-deployment.13 Studies have found that veterans with PTSD have significant impairments in social and occupational functioning and quality of life.14–18

VA and DoD healthcare providers are now facing a large population of OEF/OIF veterans who have sustained TBI, particularly mTBI, and also suffer from PTSD.19 However, the long-term health outcomes of individuals who have received diagnoses of both TBI and PTSD (TBI/PTSD), especially mTBI and PTSD (mTBI/PTSD), are poorly understood. There is concern that current evidence-based practices to define, identify, and treat mTBI and PTSD may be less accurate and/or effective when the conditions co-occur. Thus, there is a need to develop an evidence base and identify best practices for patients with this co-diagnosis. The objective of this evidence synthesis report was to systematically review and summarize the published literature that addresses the epidemiology, assessment, and treatment of adults with mTBI/PTSD. While the epidemiologic review compares prevalence estimates of PTSD across all TBI severity levels, so as to examine any potential differences in prevalence by TBI severity, the assessment and treatment sections of this report were focused on mTBI because of the growing concerns related to this injury in the U.S. military population. We emphasized results most relevant to U.S. military personnel and veterans.

## BACKGROUND

Because of the dramatic rise in the number of veterans who have sustained TBI and psychological trauma, there has been a recent spike in the literature pertaining to the overlap between the two conditions. There has been scientific debate about whether or not the history of TBI may preclude the development of PTSD.20,21 This debate stemmed mainly from the fact that PTSD by definition involves re-experiencing of traumatic events, while TBI frequently involves amnesia for the traumatic event and, thus, no memories to re-experience. For example, a study by Sbordone and Liter found that all PTSD patients were able to provide a highly detailed recollection of events occurring within 15 minutes of the traumatic event, compared with none of the patients who had sustained TBI.21 These authors suggested that history of TBI and development of PTSD are mutually exclusive events. However, since the time of their report, there has been continued documentation of PTSD developing in individuals with history of TBI, and co-occurring TBI/PTSD symptoms, across a variety of populations and TBI severity levels.24–26 Thus, it is generally accepted that the two conditions can and do co-occur.

More recently, however, researchers have proposed that symptoms often attributed to mTBI could instead be due to PTSD and other mental health problems.22,23 Hoge et al. found that, after statistical adjustment for PTSD and depression, soldiers’ mTBI history (assessed three to four months after return from deployment) no longer had a statistically significant association with physical health symptoms with the exception of headaches.22 The results of this study may reflect the normal healing process generally experienced after mTBI. It is estimated that approximately 90% of mTBI cases follow a predictable course of recovery and do not experience long-term residual symptoms requiring treatment.6,7 A small minority of individuals may experience ongoing mTBI-related psychosocial, mental, and/or physical health problems; however, a 2008 Institute of Medicine (IOM) report on the long-term consequences of TBI cited insufficient evidence of associations between mTBI and neurocognitive deficits or limitations in psychosocial functioning.24 Hoge et al. have suggested that definitions frequently used for both screening and eventual diagnosis of mTBI, especially in the presence of suspected PTSD, are methodologically inadequate, not validated, prone to bias, and potentially result in misattributing a chronic health condition to a large group of individuals.23 They particularly draw comparisons and distinctions between mTBI versus moderate and severe TBI as noted in the table below.23 Hoge et al. urge use of an approach that would “establish case definitions and evaluation tools that fulfill criteria for causation; have clinical validity and do not lead to misattribution; ensure that screening does not include nonspecific questions, is conducted near the time of injury, and maintains independence of variables; use communication strategies that promote expectations of recovery; apply knowledge from studies on the relationship between compensation and persistent post-concussive symptoms to ensure that disability regulations do not generate disability; … [develop and evaluate] evidence-based step-care and collaborative care models; and reduce the impact of flawed assumptions, conformity to consensus processes, and lack of scientific rigor on health policies and outcomes.”23 While the viewpoints by Hoge et al. are disputed for clinical purposes,28 it is noteworthy that some of their suggestions, such as stricter standardization of case definitions, would result in higher quality evidence for scientific purposes, upon which practice guidelines specific to patients with mTBI/PTSD could be based.

Comparison of Mild TBI with Moderate and Severe TBI^*^

Variable | Mild TBI (Concussion) | Moderate and Severe TBI
Clinical definition | Loss of consciousness lasting <30 minutes, any alteration of consciousness, or post-traumatic amnesia lasting <24 hrs; some definitions include Glasgow Coma Scale score of 13 to 15 | Loss of consciousness lasting ≥ 30 minutes to prolonged coma, post-traumatic amnesia lasting ≥24 hr up to permanently, or Glasgow Coma score as low as 3
Focal neurologic signs | Usually none or transient | Frequently present
Neuroimaging with CT or MRI | Usually negative | Diagnostic
Natural History | Full recovery is usual; there is lack of consensus on the natural history of concussion and post-concussive symptoms | Natural history and recovery are directly related to the severity of the injury and functional neuroanatomy
Case definitions and specificity of injury sequelae | Case definitions of post-concussive syndrome have low reliability and validity and show poor correlation with one another; there are high rates of these symptoms in healthy populations and high rates of “post-concussion syndrome” after non-head injuries | Injury sequelae are not debated
Predictors of persistent symptoms or disability | Psychological factors (e.g., depression, anxiety, or PTSD), compensation and litigation, and negative expectations and beliefs are the strongest risk factors | Directly related to injury characteristics
Neurocognitive testing | Often inconclusive beyond the period of acute injury | Essential and valuable component of on-going clinical care
Neuronal-cell damage | Metabolic and ionic processes caused by axonal twisting or stretching; these can lead to secondary disconnection | Combination of cellular disruption directly related to injury and metabolic, vascular, and ionic processes
Epidemiologic evidence of causation between injury and sequelae | Inconsistent and debated | Not debated

* CT denotes computed tomography, MRI magnetic resonance imaging, PTSD post-traumatic stress disorder and TBI traumatic brain injury.

Note: Table adapted from Hoge et al.23

There seems to be little convergent data on the prevalence, health outcomes, and treatment of TBI/PTSD. Previous reviews have highlighted the widely variable rates of overlap between diagnosis of TBI and PTSD.29–31 For example, McMillan reported that the prevalence of cases with both diagnoses ranged across studies from 1% to more than 50%,29 while Kim et al. similarly reported a range from 3% to 59%.30 Discrepancies in the reported epidemiology of TBI/PTSD may be due to differences in the true prevalence of these conditions specific to different types of trauma, levels of trauma severity, and/or baseline characteristics of the study population. Additionally, as indicated above, the methods of case ascertainment, that is, the methods, criteria, and cut-offs used to epidemiologically define and study TBI and/or PTSD “cases,” can vary widely.32 It is important to examine reported prevalence of TBI/PTSD across these potentially significant sub-categories (severity, etiology, study population, and case ascertainment) to gain a better understanding of the overlap between the two conditions.

Determining the etiology of presenting problems in individuals who have a history of mTBI as well as probable current PTSD may be complicated. While mTBI is considered a historical diagnosis and should not require the presence of current symptoms for a diagnosis to be assigned, this understanding may not be shared across all clinical disciplines that encounter mTBI patients. A number of symptoms and associated problems are common to both mTBI and PTSD. These symptoms include sleep disturbance, fatigue, depressed mood, concentration and memory problems, irritability, and reduced cognitive processing speed.26 As noted by Hoge et al., PTSD and depression may be important confounders of problems seemingly associated with an mTBI event or other physical health problems.22 Problems due to mTBI can also obstruct patients’ abilities to verbalize and describe symptoms of either condition.33 Research has also suggested that the presentation of PTSD symptoms may actually vary among individuals with and without a history of mTBI, such that different constellations of symptoms are more prominent among those with a history of brain injury (e.g., dreams, nightmares, and hyperarousal) than among those without history of brain injury (e.g., intrusive recollections).34 Additionally, the presence of other problems that commonly occur with both conditions (e.g., alcohol use, depression) may interfere with attempts to develop and complete an accurate diagnostic profile.33

It remains unknown how well diagnostic instruments currently used for assessing history and symptoms of mTBI or PTSD perform in individuals with both conditions. Without this understanding, including how rates of co-occurrence vary with different approaches to assessment, conclusions regarding the true presence and extent of overlap between mTBI and PTSD cannot be reached. Additionally, as each condition could yield alternative explanations for symptomology, accurate and differential diagnosis provides important implications for treatment. For example, avoidance of previous activities can be due to either symptoms of PTSD or the development of mTBI-related cognitive deficits. Intrusive thoughts can be explained through attempts by the patient to fill memory gaps caused by mTBI or through symptoms of PTSD.26,35 As a result, developing and evaluating appropriate treatment recommendations remains tied to accurate assessment and diagnosis of both mTBI and PTSD.

Efficacious treatment for individuals with mTBI/PTSD is of importance to VA and DoD as well as the private healthcare sector. Initial data suggest that a large number of veterans with history and/or diagnoses of both mTBI and PTSD are presenting for treatment; one study examining outcomes and service utilization of OIF veterans one-year post-deployment found that 65% of those with mTBI/PTSD reported seeking treatment for concerns related to reintegration.19 Fortunately, there are a number of efficacious psychological and pharmacological treatments for PTSD. The treatments with the strongest evidence are cognitive-behavioral psychotherapies. Effect sizes for cognitive-behavioral treatments, such as prolonged exposure therapy and cognitive processing therapy, range from medium to very large when compared to no-treatment conditions, and from small to large when compared to other psychological or psychiatric treatments.36 Among veterans, high quality studies have shown that 40% to 50% of patients no longer meet criteria for PTSD following either prolonged exposure or cognitive processing therapy.37,38 Preliminary data also suggest that such therapies will be helpful for OEF/OIF veterans. A small, ongoing trial of prolonged exposure among OEF/OIF veterans has shown a 50% reduction in PTSD symptoms following treatment.39 Data regarding the treatment of mTBI symptoms are less robust than the evidence for treatment of PTSD; however, there is evidence that providing psychoeducation regarding the typical sequelae, expected course of recovery, and compensatory strategies soon after injury may be effective in facilitating the return to premorbid functioning.40,41 The VA and DoD have recommended early education as a treatment of choice for those with a history of mTBI.6

While efficacious treatments for both mTBI symptoms and PTSD exist, patients presenting with both a history of mTBI and PTSD may need unique therapies. Patients with both conditions may experience a differential response to standard treatments compared to those with only mTBI history or PTSD. Bryant and Hopwood have identified mechanisms by which mTBI symptoms may interfere with evidence-based treatments for PTSD.20 They note that physical pain, which frequently occurs after mTBI,42 may limit the extent to which patients can engage in empirically supported treatments that involve in-person exposure to anxiety producing situations. They additionally note that cognitive limitations may make it necessary to modify cognitive-behavioral therapies, and that emotion regulation and impulse control problems may complicate the use of exposure techniques. It is unknown whether or how PTSD may conversely interfere with treatment of patients who have developed symptoms due to mTBI.

This review seeks to summarize the literature published between 1980 and June, 2009 that is specific to the epidemiology of TBI/PTSD, and to the assessment and treatment of mTBI/PTSD. It is important to note that, consistent with its definition, we have conceptualized “TBI” as a historical event and do not require the presence of current symptoms to enumerate TBI cases. However, even though a clinical interview is necessary to render a confirmed TBI diagnosis, we have included in this evidence review studies in which survey-based screening measures were used to enumerate both “probable TBI” history and current “probable PTSD.” Additionally, we have included studies that were based on data from the VA’s post-deployment screening program, in which “symptomatic probable TBI” cases are identified based on historical TBI-related events plus current symptoms potentially attributable to a TBI. We have been careful to specify studies based on screening versus clinical cases when possible.