# ACTIVE RESEARCH FINDINGS

TABLE 1 Ongoing research: Epidemiology of TBI/PTSD (Key Question #1)

Principal Investigator | Project Title/Status | Main Objective(s) | Study Characteristics
Copeland, L. | Tracking OEF/OIF Transition from DoD to VA Status: Completed, article in preparation | 1. Determine feasibility of DoD-to-VA transfer of PHI on a local level 2. Determine rate of transition of Wounded Warriors from Brooke Army Medical Center to VA healthcare system 3. Determine use of VA mental healthcare NOTE: TBI diagnosis obtained from medical records | Study Design: Observational cohort Population: OEF/OIF deployed personnel treated and discharged from Brooke Army Medical Center (BAMC) FY02-FY07 Intervention: None Comparator: None Outcomes: Prevalence of PTSD at BAMC and at VA; delay from discharge at DoD to diagnosis/treatment of PTSD in VA system Timing: From discharge at DoD to treatment at VA Setting: Army Medical Center and VA sites
Donnelly, K. (See Appendix E, Table 2) | Cognitive Assessment of Veterans after Traumatic Brain Injury Status: In progress | 1. Describe war-related cognitive and affective symptoms and patterns of substance abuse in OEF/OIF veterans 2. Construct cognitive and affective profiles of OEF/OIF veterans over time 3. Describe the temporal relationship between composite stress index and cognitive profiles of OEF/OIF veterans 4. Describe the temporal relationships among TBI, cognitive symptoms, patient outcomes, and health services outcomes | Study Design: Prospective cohort Population: 500 OEF/OIF veterans Intervention: None Comparator: None Outcomes: TBI identified with structured diagnostic interview; PTSD identified with PTSD checklist Timing: Baseline, 6, 12, and 18 mos Setting: 5 outpatient VA sites (VISN 2)
Griffin, J. | Understanding and Meeting the Needs of Informal Caregivers to Improve Outcomes for TBI patients with Polytrauma Status: In progress | Assess the relationship between caregiving and patient, caregiver, and family health outcomes, including the physical, emotional, and financial burden of caregiving and the resources available to caregivers | Study Design: Observational Population: Family caregivers of all OEF/OIF patients with a TBI discharged from a Polytrauma Rehabilitation Center (PRC) Intervention: None Comparator: None Outcomes: Caregiver-report of patients’ TBI and PTSD diagnoses Timing: At least 3 mos post-discharge from PRC Setting: Surveys administered by mail
Kang, H. (See Appendix E, Table 2) | National Health Study for a New Generation of U.S. Veterans Status: In progress | 1. Determine if the health status of OEF/OIF veterans is better, worse, or the same as non-deployed veterans 2. Characterize healthcare utilization and VA disability compensation patterns of OEF/OIF veterans 3. Describe the natural histories of psychological disorders, mTBI, musculoskeletal problems, and other health conditions over time among veterans 4. Obtain prevalence figures for mTBI and PTSD from a population-based sample | Study Design: Longitudinal Population: 30,000 deployed OEF/OIF veterans and 30,000 non-deployed OEF/OIF era veterans Intervention: None Comparator: None Outcomes: TBI and PTSD identified with screening instruments used in VAMCs Timing: 10 year follow-up with assessment every 3 years Setting: Surveys administered by mail, on-line, and by telephone
Polusny, M. | Mild TBI/PTSD Comorbidity and Post-Deployment Outcomes in National Guard Soldiers Status: Completed, manuscripts in preparation | 1. Describe the scope of mTBI/PTSD among returning National Guard OIF veterans 2. Identify the extent to which these problems impacted veterans’ psychosocial functioning, physical health, and quality of life over time 3. Examine variation in new OIF veterans’ experiences with VA by mTBI and probable PTSD status | Study Design: Two-wave longitudinal cohort Population: OIF National Guard soldiers Intervention: None Comparator: None Outcomes assessed: In-theater: blast exposure, mTBI, PTSD symptoms; Post-deployment: combat exposure, exposure to explosive blasts and injuries sustained, mTBI and post-concussive symptoms, current psychosocial functioning, physical health, access and use of VA healthcare services Timing: In-theater screening one-month before returning home; mailed survey at 1 year post-deployment Setting: In-theater and home
Rao, V. | Post-Traumatic Brain Injury Depression Status: In progress | To identify risk factors for depression among patients with first time TBI (all severity levels) (NOTE: PTSD assessed with full structured interview) | Study Design: Prospective, observational Population: 140 consecutive TBI patients; recruited soon after injury Intervention: None Comparator: None Outcomes: Major depression; also assessing PTSD Timing: Follow-up at 1 year post-injury Setting: Clinical (2 university-affiliated trauma units)
Tupler, L. (See Appendix E, Table 2) | TBI Severity and Associated Neurocognitive findings in OEF/OIF Veterans Status: Data collection complete; analysis in progress | To examine the epidemiology of TBI in OEF/OIF veterans and the relationship between self-reported severity of TBI and level of PTSD symptomatology and neurocognitive performance (NOTE: results to be analyzed by severity of TBI) | Study Design: Prospective, observational Population: Approximately 850 OEF/OIF veterans; TBI and PTSD status unknown by investigators at time of enrollment Intervention: None Comparator: None Outcomes: Neurocognitive and psychological test battery (including PTSD Checklist) findings examined in relation to TBI history (chart review or self-report) Timing: Post-deployment; time from TBI assessed Setting: One Polytrauma Rehabilitation Center, three Level III Polytrauma Support Clinic Teams

TABLE 2 Ongoing research: Assessment of mTBI/PTSD (Key Question #2)

Principal Investigator | Project Title/Status | Main Objective(s) | Study Characteristics
Donnelly, K. (See Appendix E, Table 1) | Cognitive Assessment of Veterans after Traumatic Brain Injury Status: In progress | Describe the psychometric properties of the VA TBI screening tool | Study Design: Prospective cohort Population: 500 OEF/OIF veterans Intervention: None Comparator: None Outcomes: Item analysis of the VA TBI screening tool; test-retest reliability and sensitivity/specificity with structured diagnostic interview for TBI probability/severity as criterion Timing: Baseline, 6, 12, and 18 mos Setting: 5 outpatient VA sites (VISN 2)
Kang, H. (See Appendix E, Table 1) | Markers for the Identification, Norming, and Differentiation of TBI and PTSD (MIND) Status: Planning stage | 1. Clarify differential diagnoses between TBI and PTSD 2. Build objective, consistent, and operator-independent diagnostic criteria | Study Design: Cross-sectional Population: Subset of OEF/OIF veterans from New Generation study with TBI and/or PTSD and a comparison group Intervention: None Comparator: None Outcomes: Advanced diagnostic tests (neuroimaging, sleep studies, neuroendocrine measures) Timing: One-time testing; patients continue enrollment in New Generation study Setting: VA War Related Illness and Injury Study Centers
Rao, S. Levin, H. | Neural and Behavioral Sequelae of Blast-Related Traumatic Brain Injury Status: In progress | Identify the similarities and potential differences in the neural and behavioral sequelae of blast-related TBI compared to mechanically-induced TBI occurring in civilians | Study Design: Prospective, cross-sectional observational Population: n=120 in 4 groups – military with mild to moderate TBI, military with mild to moderate orthopedic injury (OI), civilian with mTBI, civilian with OI Intervention: None Comparator: None Outcomes: Advanced MRI findings, neuropsychological test results, post-concussion symptoms, PTSD symptoms, depression, pain and fatigue scales Timing: Assessment at 12–24 mos post-injury Setting: Cleveland and Houston VAMCs; community hospital trauma/rehabilitation centers
Tupler, L. (See Appendix E, Table 1) | TBI Severity and Associated Neurocognitive findings in OEF/OIF Veterans Status: Data collection complete; analysis in progress | Examine the relationship between self-reported severity of TBI and level of PTSD symptomatology and neurocognitive performance on a measure of premorbid intellectual functioning and prefrontal verbal abstraction (NOTE: results to be analyzed by severity of TBI) | Study Design: Prospective, observational Population: Approximately 850 OEF/OIF veterans; TBI and PTSD status unknown by investigators at time of enrollment Intervention: None Comparator: None Outcomes: Neurocognitive and psychological test battery (including PTSD checklist) findings examined in relation to TBI history (chart review or self-report) Timing: Post-deployment Setting: One Polytrauma Rehabilitation Center, three Level III Polytrauma Support Clinic Teams
Tupler, L. | Posttraumatic Stress Disorder with and without Traumatic Brain Injury: Comorbidity and Longitudinal Course of Recovery Status: Preparing for data analysis | Examine neurocognition in OEF/OIF post-deployed and active-duty personnel with TBI alone, PTSD alone, and comorbid TBI and PTSD compared with combat controls and non-combat controls (NOTE: same population as in study described below) | Study Design: Prospective, observational Population: Approximately 170 OEF/OIF veterans and active-duty personnel Intervention: None Comparator: None Outcomes: Neurocognitive and psychological test battery (including PTSD checklist) findings examined in relation to TBI history (chart review or self-report) Timing: Continuous recruitment since 2006 Setting: One Polytrauma Rehabilitation Center, two Level III Polytrauma Support Clinic Teams
Tupler, L. | Can Olfaction be used to Discriminate Traumatic Brain Injury from Posttraumatic Stress Disorder? Status: Preparing for data analysis | Examine the utility of the University of Pennsylvania Smell Test (UPSIT) as a means of discriminating TBI from PTSD (NOTE: same population as in study described above) | Study Design: Prospective, observational Population: Approximately 170 OEF/OIF veterans and active-duty personnel Intervention: None Comparator: None Outcomes: UPSIT and PTSD Checklist in relation to TBI history (chart review or self report) Timing: Continuous recruitment since 2006 Setting: One Polytrauma Rehabilitation Center, two Level III Polytrauma Support Clinic Teams
Vanderploeg, R. Fitzgerald, S. | TBI Screening Instruments and Processes for Clinical Follow-up Status: In progress | Evaluate the reliability and validity of the existing Traumatic Brain Injury (TBI) Clinical Reminder Screen for OEF/OIF Veterans controlling for comorbidities and demographics | Study Design: Diagnostic test evaluation Population: OEF/OIF veterans Intervention: None Comparator: None Outcomes: Reliability and validity Timing: Not stated Setting: VA Polytrauma Rehabilitation Centers, Network Sites, and Support Clinic Teams

TABLE 3 Ongoing research: Treatment of mTBI/PTSD (Key Question #3)

Principal Investigator | Project Title/Status | Main Objective(s) | Study Characteristics
Beckham, J. | Rehabilitation Strategies to Reduce Violence and Anger in TBI and PTSD Status: Proposal under review | 1. Identify risk and protective factors empirically related to violent behavior among veterans who have returned from Iraq and Afghanistan 2. Examine the link between specific factors related to violence among veterans from previous conflicts and post-deployment violence risk among Iraq and Afghanistan veterans 3. Develop an evidence-based risk assessment instrument to administer to Iraq and Afghanistan veterans in order to identify those most in need of services | Study Design: Prospective cohort Population: 300 OEF/OIF veterans and a member of their family Intervention: None Comparator: None Outcomes: Modality of psychotherapy, dosages and classes of psychiatric medications Timing: Interview at baseline and 6 mos Setting: VA, outpatient NOTE: although the direct aim of the study is not to evaluate particular rehabilitation strategies, the investigators believe that information yielded from the study may be useful in sequencing treatment efforts
Epstein, D. | Pilot Test of Preference-Based Insomnia Treatment for OEF/OIF Veterans Status: Proposal under review | Pilot test a brief, preference-based insomnia intervention augmented by audio files (MP3) and web-based resources | Study Design: One group, pre-post Population: 26 OEF/OIF veterans, history of blast exposure or other injury resulting in period of altered consciousness AND insomnia complaint of ≥ 1 mo. duration with daytime impairment, Insomnia Severity Index (ISI) ≥ 10, phone and internet access, ability to listen to audio files on MP3 player Intervention: Multi-component – relaxation therapy, mindfulness exercise, stimulus control instructions, sleep restriction therapy, and sleep education and hygiene Comparator: None Outcomes: ISI, Pittsburgh Sleep Quality Index-Addendum for PTSD (PSQI-A), daily sleep diary, treatment feasibility Timing: 4 week treatment phase, assessed pre-treatment, during treatment, and 2 weeks post-treatment Setting: VA, outpatient
Nichols, L. Martindale-Adams, J. | Team Based Initiative: Support (Pilot) Status: Completed, report in development | 1. Determine the feasibility of implementing volunteer support teams with TBI families 2. Identify the obstacles and opportunities in implementation | Study Design: Case series Population: Family members of 6 Guard/Reserve service members (OEF/OIF veterans) with mild-complicated TBI and co-occurring PTSD Intervention: Project coach for needs assessment, team formation, training Comparator: None Outcomes: Qualitative data on family issues and concerns Timing: Returning to community post-injury Setting: Outpatient (family homes), rural
Harch, P. | Pilot Study of Hyperbaric Oxygen Therapy (HBOT) in Chronic Traumatic Brain Injury (TBI)/Post-Concussion Syndrome (PCS) and TBI/Post-Traumatic Stress Disorder (PTSD) Status: In progress | Determine if one or two 40-treatment courses of low pressure HBOT can improve cognition and brain imaging in subjects with either chronic mild-moderate TBI (also known as PCS), or chronic TBI with PTSD secondary to blast injury | Study Design: Open-label, single group Population: 30 patients (15 with TBI, 16 with TBI and PTSD), 18–45 years old, blast-induced injury resulting in mTBI/concussion with loss of consciousness; able to manage self-care Intervention: 40 (or 80) HBOT sessions; 2 sessions per day for 20 days (4 weeks) Comparator: None Outcomes: Psychometric and neuropsychological tests, brain imaging Timing: Injury 1 to 4 years prior to enrollment; baseline assessment, post-treatment assessment, and follow-up at 6 mos and 1 year post-treatment Setting: Non-VA clinic
Ruff, R. | Improving Sleep: Initial Treatment in OIF/OEF Veterans with Blast-Induced Mild TBI Status: Completed, publication in development | Determine if treating impaired sleep would reduce headache frequency and severity | Study Design: Case series Population: OIF/OEF veterans with headaches associated with mTBI and persisting neurocognitive deficits Intervention: Education in sleep hygiene and prazosin to reduce nightmares associated with PTSD Comparator: Patients who do not complete prazosin protocol or who discontinued prazosin after intervention period Outcomes: Headache frequency and severity, cognitive assessment, sleep assessment Timing: Assessment at baseline, after 9 week intervention, 6 mo. follow-up Setting: Outpatients from VAMC