# EVIDENCE TABLES

TABLE 1 Details of published studies evaluated in Key Question 1

Study/Country | Study design and population | n | Characteristics of participants | Prevalence of TBI history with PTSD | Traumatic brain injury definition/measure | Post-traumatic stress disorder assessment
Brenner 2009^79^ United States | Cross-sectional Veterans receiving services related to TBI and/or PTSD | N=72; 82% (n=59) with TBI; 63% with PTSD (n=45) | Data for all study subjects Trauma etiology: NR TBI severity: 46% mild; 17% moderate; 36% severe Time of assessment or since trauma: Median = 23 years (1–53) Mean age: 52 (9.7) years Women: 10% Race: Caucasian 65%; Hispanic 19%; African American 10%; Other 4% Education: Less than high school 3%; high school graduate 26%; more than high school 71% Pain: NR Other mental health conditions: NR | 44% (n=32) of all subjects [89% of subjects with mild TBI; 36% of subjects with moderate TBI; 19% of severe TBI] | Interview and chart review. | Structured Clinical Interview for DSM-IV (SCID-IV).
Chalton 2009^80^ United Kingdom | Cross-sectional Patients recruited from a hospital outpatient head injury clinic | N=21; all TBI | Data for all study subjects Trauma etiology: MVC 43%; fall 29%; assault 24%; work-related accident 5% TBI severity: 19% mild; 19% moderate; 62% severe Time of assessment or since trauma: 3–359 mos (median = 14) Mean age: 42.90 (10.98) Women: 33% Race: NR Education: 12.61 (2.85) years Pain: NR Other mental health conditions: 60% anxious (30% mild; 30% moderate or severe); 35% depressed (15% mild; 15% moderate) | 14% (n=3) of all subjects [0% of subjects with mild TBI; 50% of subjects with moderate TBI; 8% of subjects with severe TBI] | Retrospective assessment of post-traumatic amnesia. | Clinician Administered PTSD Scale (CAPS).
Mora 2009^81^ United States | Cross-sectional Record review of OEF/OIF soldiers with and without blast injuries treated at the United States Army Institute of Surgical Research Burn Center | n=119 22% with PTSD; 18% with TBI (all but one mTBI) | Data for all study subjects Trauma etiology: Military 100% TBI severity: Mild 95%; severe 5% (n=1) Time of assessment or since trauma: 193.7 (171.9) days for blast injury group; 189.7 (175.2) days for no blast injury group Mean age: 26.3 (6.1) for blast injury group; 25.9 (6.0) for no blast injury group Women: 15% blast injury group; 4% no blast injury group Race: NR Education: NR Pain: NR Other mental health conditions: NR | 6% (n=7) of all subjects; 35% of mTBI subjects (PTSD status for 1 severe TBI case not reported) | Record review, loss of consciousness served as definition for mTBI. | Self report through PCL-M (> 44 required for PTSD diagnosis).
Gaylord 2008^52^ United States | Cross-sectional Service members identified through Trauma Burn Registry | n=76, 31 with TBI | Data for all study subjects Burned veterans, TBI vs. no TBI Trauma etiology: Combat (blast and burn) 100% TBI severity: mild 100% Time of assessment or since trauma: NR Mean age: 26 Women: 4% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 18% (n=14) of all subjects; 45% of TBI subjects | Medical records and clinical interviews. Glasgow Coma Scale (≥ 13), loss of consciousness (< 30 mins) and/or post-traumatic amnesia (≤ 24 h). | Self-report through PTSD Checklist (PCL-M). Score of 44+ indicative of PTSD.
Ruff 2008^53^ United States | Cross-sectional Subjects evaluated as part of care in VA Medical Center | n=126; all TBI | Data for all study subjects OEF/OIF war veterans Trauma etiology: Combat (blast) 100% TBI severity: mild 100% Time of assessment or since trauma: 30 mos (range 8 mos – 4.5 years) Mean age: NR Gender: NR Race: NR Education: NR Pain: 63% (headache) Other mental health conditions: NR | 66% (n=83) of all subjects | Administrative data based on positive Veterans Affairs (VA) 4-item TBI screen, including loss of consciousness (< 30 mins) and/or post-traumatic amnesia (< 24 h) and/or alteration of consciousness (< 24 h). | Self-report through PCL. Score of 50+ indicative of PTSD.
Hoge 2008^22^ United States | Cross-sectional Army infantry soldiers surveyed while on duty | n=2525 819 injured; 384 with TBI. 1706 not injured | Data for all study subjects Iraq war veterans Trauma etiology (subjects with TBI, can have more than one source of injury): Blast/explosion 75%; fall 29%; MVC 22% TBI severity: mild 100% Time of assessment or since trauma: 3–4 mos post-deployment Mean age: NR Women: 5% Race: NR Education: less than HS 42%; HS grad 58% Pain: 30% (arm, leg, or joint pain; most frequently endorsed pain); 11% (headache) Other mental health conditions: Depression 11% | 5% (n=125) of all subjects; 33% of TBI subjects | Self-report, a) loss of consciousness (n=124 subjects); and b) altered mental status (dazed, confused loss of memory) (n=260 subjects). | Self-report through PCL. Score of 50+ indicative of PTSD.
Koenigs 2008^54^ United States | Cohort Vietnam veterans in the Vietnam Head Injury Study | n=245; 193 with TBI | Data for all study subjects Vietnam veterans Trauma etiology: Combat 100% TBI severity: penetrating 100% Time of assessment or since trauma: NR Mean age: NR Gender: NR Race: NR Education: NR Pain: NR Other mental health conditions: NR | 25% (n=62) of all subjects; 32% of TBI subjects | NR. | Structured clinical interview (SCID), based on DSM-IV criteria.
Schneiderman 2008^55^ United States | Cross-sectional Surveyed OEF/OIF veterans who served prior to October 2004 and lived in geographic catchment area | n=2235; 275 with TBI | Data for all study subjects OEF/OIF war veterans Trauma etiology (could have more than 1): Combat 34% (blast 74%, non-blast 26%); falls 39%; sports/physical training 28%; MVC 20% TBI severity: mild 100% Time of assessment or since trauma: NR Age groups: 18–25 18%; 26–30 15%; 31–35 16%; 36–40 17%; 41+ 38% Women: 13% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 5% (n=109) of all subjects; 39% of TBI subjects | Self report, Brief Traumatic Brain Injury Screen. | Self report through PCL. Score of 50+ indicative of PTSD.
Schwartz 2007;^55^ Schwartz 2008^88^ Israel | Case-control, terror vs. nonterror Patients treated in hospital PM&R unit | n=144; 38 with TBI | Data for all study subjects Trauma etiology: Terror subgroup - blast 70%, gunshot 30%. Non-terror subgroup – MVC 82%; fall 17% TBI severity: mild 32%; moderate 21%; severe 47% Time of assessment or since trauma: end of rehab stay – terror 218 ± 131 days, non-terror 152 ± 114 days Mean age (range): 30 (9–76) Women: 33% Race: NR Education: Less than HS 15%; HS grad 47%; “student” 8%; college grad 29% Pain: NR Other mental health conditions: NR | 11% (n=16) of all subjects; 42% of TBI subjects in terror subgroup; 42% of TBI subjects in non-terror subgroup [Prevalence not reported by TBI severity] | Based on Glasgow Coma Scale scores and brain computed tomography (CT). | Semi-structured interview; Revised PTSD Inventory (Solomon et al., 1993). Instrument based on Brief Symptoms Inventory.
Bombardier 2006^57^ United States | Cohort Subjects recruited from trauma hospital | n=125; all TBI | Data for all study subjects Trauma etiology: MVC 49%; assault 7% TBI severity: mild 44%; moderate 30%, severe 27% Time of assessment or since trauma: NR Mean age: 43 Women: 23% Race: white 92%; black 6% Education: HS grad 85% Pain: NR Other mental health conditions: 71% of TBI/PTSD subjects had a history of depression or anxiety symptoms unspecified | 11% (n=14) of all subjects [9% (n=5) with mild TBI; 8% (n=3) with moderate TBI; 18% (n=6) with severe TBI] | Medical record, based on Glasgow Coma Scale score. | PCL administered as a structured interview. Score of moderate severity on one intrusive, three avoidant, and two arousal symptoms indicative of PTSD.
Greenspan 2006^58^ United States | Cohort Subjects identified from TBI databases after discharge from trauma hospitals | n=198; all TBI | Data for all study subjects Trauma etiology: MVC 70%; fall 16%, pedestrian injury 6%; other 8% TBI severity: mild 19%; moderate 21%; severe 60% Time of assessment or since trauma: 3 years Mean age: 35 Women: 34% Race: white 74%; black 23%; other 3% Education: Less than HS grad 32%; HS grad 34%; at least some college 34% Pain: NR Other mental health conditions: NR | 11% (n=22) of all subjects at 6 mos post-injury; 16% at 12 mos post-injury [Prevalence not reported by TBI severity] | Received treatment for head injury at hospital. | Self-report through the IES. Score of 35+ indicative of PTSD.
Creamer 2005^59^ Australia | Cohort Subjects were consecutive admissions to a level 1 trauma hospital | n=307; 189 with TBI | Data for all study subjects Trauma etiology: NR TBI severity: mild 100% Time of assessment or since trauma: mean 8 days Mean age: 37 Women: 24% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 8% (n=24) of all subjects; 15% of TBI subjects | Loss of consciousness of ≤ 30 minutes, PTA ≤ 24 hours, and GCS of ≥ 13 30 minutes post-trauma. | CAPS, amnesia eliminated as a symptom.
Gil 2005^60^ Israel | Cross-sectional Recruited from 2 surgery wards after treatment for TBI | n=120; all TBI | Data for all study subjects Trauma etiology: MVC 90% TBI severity: mild 100% Time of assessment or since trauma: within 24 h after hospitalization; 7–10 days, 4 weeks, 6 mos Mean age: 31.4 Women: 42% Race: NR Education: 13 years (mean) Pain: NR Other mental health conditions: NR | 14% (n=17) of all subjects at 6 mos post-injury | Presenting to hospital/clinic for TBI (all had GCS 13–15). | CAPS.
Jones 2005^61^ England | Cohort Subjects were consecutive patients in hospital Accident and Emergency Department | n=131; 66 with TBI 118 at 6 weeks; 56 with TBI 74 at 3 mos; 58 with TBI | Data for all study subjects Trauma etiology: MVC 100% TBI severity: mild 100% Time of assessment or since trauma: 6 weeks and 3 mos Mean age (range): 37 (18–65) Women: 60% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 14% (n=17) of all subjects at 6 weeks; 30% of TBI subjects 14% (n=10) of all subjects at 3 mos; 17% of TBI subjects | Post-traumatic amnesia (< 24 h), as described by Gronwall and Wrightson (1980). | PTSD Symptom Scale (PSS). Amnesia eliminated as a symptom.
Sumpter 2005^62^ United Kingdom | Cross-sectional Subjects recruited from community outpatient and rehabilitation services, and volunteer organizations | n=34; all TBI | Data for all study subjects Trauma etiology: MVC 47%; fall 32%; assault 18%; sports injury 3% TBI severity: severe 100% Time of assessment or since trauma: 6 year (0.6–34) Mean age (range): 40 (20–60) Women: 12% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 3% (n=1) of all subjects | NR. Subjects with severe TBI recruited from community out-patient and rehabilitation services and voluntary organizations. | CAPS, requiring clinical judgment of symptoms being related to trauma. (compared to 3 other methods of assessment.)
Ashman 2004^63^ United States | Cohort Subjects recruited from medical centers, brain injury associations, newspaper and website advertisements, and word-of-mouth | n=188; all TBI 83 at 24 mos; all TBI | Data for all study subjects Trauma etiology: NR TBI severity: mild 29%; moderate-severe 62%; 9% unknown Time of initial assessment or since trauma: 3 mos – 4 years Mean age (range): 40 (18–87) Women: 47% Race: white 72%; black 12% Education: Less than high school 27%; HS/some college 38%; college graduate 25% Pain: NR Other mental health conditions at time 1: Depression 35%; Anxiety symptoms unspecified 27%; Substance use disorder (SUD) 14% | 30% (n=56) of all subjects at time 1 (initial assessment between 3 mos and 4 years postinjury) 18% (n=34) of all subjects at time 2 (12 mos after initial assessment) 21% (n=17) of all subjects at time 3 (24 mos after initial assessment) [Prevalence not reported by TBI severity] | Self-reported; severity determined using ACRM loss of consciousness criteria. | SCID, based on DSM-IV criteria.
Williams 2002^64^ United Kingdom | Cross-sectional Subjects recruited through brain injury services | n=66; all TBI | Data for all study subjects Trauma etiology: MVC 45%; falls 18%; assault 3% TBI severity: severe 100% Time of assessment or since trauma: mean 5.9 years (range 1–26 years) Mean age (range): 38 (17–70) Women: 24% Race: NR Education: mean 12 years (range 9–19 years) Pain: NR Other mental health conditions: NR | 18% (n=12) of all subjects | Self-report, based on loss of consciousness (+6 hrs) and/or posttraumatic amnesia (≥ 1 day). | Self-report through IES, corroborated by relative or caregiver. Score of 26+ indicative of PTSD.
Berthier 2001^65^ Spain | Case series Consecutive referrals to Behavioral Neurology Unit of a single University Hospital; all patients diagnosed with OCD after TBI | n=10; all TBI (all OCD) | Data for all study subjects Trauma etiology: MVC 100% TBI severity: mild 60%; moderate 20%; severe 20% Time of assessment or since trauma: > 51 mos Mean age: 30 Women: 60% Race: NR Education: mean 11 years Previous head injury: 0% Pain: NR Other mental health conditions: Obsessive-compulsive disorder 100%; depression 90% | 70% (n=7) of all subjects [60% (n=6) with mild TBI; 10% (n=1) with moderate TBI; 0% with severe TBI] | Glasgow Coma Scale score, determined at hospital admission. | SCID, based on DSM-III-R criteria.
Hoofien 2001^66^ Israel | Cohort Participants from a larger longitudinal study of patients from a single neuropsych rehab center with medically documented TBI at least 5 years before study | n=76; all TBI | Data for all study subjects Trauma etiology: MVC 64%; combat 25%; work-related 9% TBI severity: severe 100% Time of assessment or since trauma: 14± 5.8 (SD) years Mean age (range): 25 (17–50) age at injury Women: 83% Race: NR Education: NR Pain: NR Other mental health conditions: Depression 45% | 10% (n=7) of 68 responding to PTSD items | Subjects were in a coma for an unspecified long period of time. | Post-Traumatic Stress Disorder Inventory, based on DSM-III criteria. “Probable PTSD” diagnosis assigned to subjects meeting 4 criteria: traumatic event, re-experiencing, numbing, and hyperarousal symptoms.
McCauley 2001^67^ United States | Cohort Participants recruited from Emergency Center or inpatient unit of a single Level-1 trauma center | n=200; 115 with TBI | Data for all study subjects Trauma etiology: MVC 69%; assault 15%; other 16% TBI severity: mild 83%; moderate 17% Time of assessment or since trauma: 88 days Mean age: 34 Women: 78% Race: Hispanic 52%; black 32%; white 16% Education: mean 11 years Pain: NR Other mental health conditions: Depression 9% | 8% (n=15) of all subjects; 13% of TBI subjects [12% (n=11) of subjects with mild TBI; 15% (n=4) of subjects with moderate TBI] | Hospital admission logs (“non-penetrating head injury” based on Glasgow Coma Scale scores 9–15). | SCID, based on DSM-IV criteria.
Turnball 2001^78^ United Kingdom | Cross-sectional Subjects attended an Accident and Emergency Unit following a traumatic event and had evidence of TBI in medical record | n=53; all TBI | Data for all study subjects Trauma etiology: assault 58%; MVC 30%; fall 11% TBI severity: mild 58%; moderate 21%; severe 17%; none 2 subjects Time of assessment or since trauma: 5 mos Mean age: 35 Women: 13% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 17–27% of all subjects [Prevalence not reported by TBI severity] | Based on history of post-traumatic amnesia. | Those with IES-R score ≥ 20 administered the CAPS, with amnesia excluded as a symptom. Results reported using the most strict and most lenient cutoffs as recommended by scale authors on the CAPS.
Bryant 1999a;68 Bryant 2000;^89^ Bryant 2000;^90^ Bryant 2001;^91^ Bryant 2004^92^ Australia | Cohort Consecutive admissions to single site major brain injury rehab unit | n=96; all TBI | Data for all study subjects Trauma etiology: MVC 73%; industrial injury 15%; assault 13% TBI severity: mild 100% Time since trauma: 6 mos Mean age: 34 Women: 20% Race: NR Education: NR Pain: 58% report daily pain; M = 6.90 (2.65) on a 1–10 severity scale Other mental health conditions: NR | 27% (n=26) of all subjects | Medical records based on Glasgow Coma Scale score and post-traumatic amnesia (Westmead PTA scale). | Post-traumatic Stress Disorder Interview (PTSD-I; Watson et al., 1991), based on DSM-III-R criteria.
Bryant 1999b;69 Australia | Cohort Consecutive admissions to single site major trauma hospital following MVC | n=105; 46 with TBI | Data for all study subjects Trauma etiology: MVC 100% TBI severity: mild 100% Time of assessment or since trauma: 6 mos Mean age: 31 Women: 40% Race: NR Education: NR Pain: Headaches in 100% of subjects with mTBI/PTSD Other mental health conditions: NR | 9% (n=9) of all subjects; 20% (n=9) of TBI subjects | Hospital admissions, post-traumatic amnesia < 24 h, loss of consciousness. | Composite International Diagnostic Interview (CIDI).
Bryant 1998^70^ Harvey 2000^93^ Australia | Cohort Consecutive MVC victims treated at a single site major trauma hospital with evidence of TBI | n=79; all TBI | Data for all study subjects Trauma etiology: MVC 100% TBI severity: mild 100% Time of assessment or since trauma: mean 7.15 days (range 2–28); PTSD assessed 6 mos and 2 years post-trauma Mean age (range): 29 (16–60) Women: 30% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 24% (n=15) of 63 subjects assessed at 6 mos; 22% (n=11) of 50 subjects assessed at 2 years | Hospital admission, post-traumatic amnesia < 24 h. | Composite International Diagnostic Interview (CIDI).
Hibbard 1998^71^ United States | Cross-sectional Participants randomly selected from 431 individuals with TBI involved in a larger quality of life survey | n=100; all TBI | Data for all study subjects Trauma etiology: MVC 62%; assault 8%; other 30% TBI severity: NR Time of assessment or since trauma: mean 7.6 years Mean age: 40 Women: 47% Race: white 73%; black 14%; Hispanic 9% Education: HS grad or less 29%; some college/college grad 49% Pain: NR Other mental health conditions: Depression 61%; SUD 28%; obsessive-compulsive disorder (OCD) 15%; panic disorder 14% ; phobias 10% ; general anxiety disorder 9% | 19% (n=19) of all subjects | Self-reported loss of consciousness. | SCID, based on DSM-IV criteria.
Hickling 1998^72^ United States | Cross-sectional Subjects were recently in and sought medical treatment within 2 days for MVC | n=107; 16 with TBI | Data for all study subjects Trauma etiology: MVC 100% TBI severity: NR Time since trauma: 1–4 mos Mean age: 35.9 Women: 69% Race: 9.3% “minorities” Education: NR Pain: NR Other mental health conditions: NR | 8% (n=9) of all subjects; 56% of subjects with TBI (9 of 16) | Clinical screening – rates of TBI stratified across multiple types of injury that varied in likelihood of producing TBI – only strictest criterion (e.g., loss of consciousness) used in the present review as evidence of TBI. | Clinician-Administered PTSD Scale (CAPS).
Trudeau 1998^73^ United States | Cross-sectional Outpatient male combat veterans from a PTSD treatment program and/or addictive disorders treatment program with a diagnosis of PTSD | n=43; all PTSD | Data for all study subjects Trauma etiology: Combat 100% (27 with a blast concussion and 16 without) TBI severity: mild 60%; moderate 40% Time of assessment or since trauma: NR Mean age (range): 52 (26–72) Women: 0% Race: NR Education: NR Pain: NR Other mental health conditions: SUD 42%; Attention-deficit/hyperactivity disorder (ADHD) 16% | 60% (n=25) of 42 respondents [Prevalence not reported by TBI severity] | Self-report, either a) being in the presence at a detonation of ordnance, often resulting in death or serious injury to others closer to blast, b) experiencing unconsciousness for ≤ 20 mins or dazed for ≥ 1 hour without loss of consciousness, or c) requiring medical attention for concussive episode. | Not described, all subjects were enrolled in a PTSD recovery program and/or addictive disorders treatment program and had a clinical diagnosis of PTSD.
Warden 1997^74^ United States | Cohort Consecutive active duty service members with a moderate TBI at Walter Reed Army Medical Center | n=41; all TBI | Data for all study subjects Trauma etiology: MVC 70%; fall 19%; assault 9% TBI severity: moderate 100% Time of assessment or since trauma: 4–29 mos Mean age: 27 Women: 2% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 11% (n=3) of 28 subjects at 8 weeks post-injury; 20% (n=3) of 15 subjects at 6 mos post-injury; n=0 of 18 subjects at 12 mos postinjury; 14% (n=1) of 7 subjects at 24 mos post-injury | Based on history of post-traumatic amnesia and Rancho Los Amigos scale. | Present State Examination, additional PTSD questions added to assess full spectrum of PTSD symptoms (e.g., added symptoms about re-experiencing and avoidance). Memory of event not required. Administered by clinicians.
Powell 1996^75^ United Kingdom | Cohort Participants recruited from a hospital who were admitted for observation following mild/moderate TBI | n=35; all TBI | Data for all study subjects Trauma etiology: MVC 34%; dom. assault 29%; assault 14%; sport/other 14%; industrial 3% TBI severity: mild 69%; moderate 31% Time of assessment or since trauma: 3 mos Mean age: 35 Women: 34% Race: NR Education: NR Pain: NR Other mental health conditions: Depression 9% | 34% (n=12) of all subjects [25% of subjects with mild TBI; 55% of subjects with moderate TBI] | Based on Glasgow Coma Scale, subjects admitted to hospital for minor head injury. | Self report through IES (>26 required for a positive screen for PTSD).
Sbordone 1995^21^ United States | Cross-sectional Participants diagnosed with post-concussive syndrome or PTSD prior to study recruitment; No information provided on method or location of recruitment | n=70; 28 with TBI, 42 with PTSD | Data for all study subjects Trauma etiology: MVC 66%; blunt head trauma 14%; fall 10%; other 10% TBI severity: mild 100% Time of assessment or since trauma: TBI 20.8 ± 16.4 mos; PTSD 29.1 ± 32.7 mos Mean age: 37 Women: 41% Race: NR Education: NR Pain: NR Other mental health conditions: NR | 0 TBI subjects had PTSD | Unstructured interview by first author. | Unstructured interview by first author.
Middelboe 1992^76^ Denmark | Cohort Consecutive patients admitted to a hospital Neurology Department with clinical evidence of TBI | n=28; all TBI | Data for all study subjects Trauma etiology: NR TBI severity: mild 100% Time since trauma: 3 mos & 1 year Mean age: 37 Women: 46% Race: NR Education: NR Pain: 32% reported headaches at 1 year post-TBI Other mental health conditions: NR | 0 subjects had PTSD; 11% with “high” IES scores (above 19) 1 year post-trauma | Through neurologic exam (not specified). | Self-report through IES and unspecified symptom checklist. Information regarding how PTSD diagnosis was established not provided.

TABLE 2 Details of RAND study evaluated in Key Question 1

Study/Country | Study design and population | n | Characteristics of participants | Prevalence of TBI history with PTSD | Traumatic brain injury definition/measure | Post-traumatic stress disorder assessment
RAND 2008^5^ United States | Cross-sectional OEF/OIF service members and veterans identified through random digit dialing using telephone exchanges encompassing 24 geographic areas | n=1965; 19.5% with TBI (weighted percentage) | Data for all study subjects Trauma etiology: Military 100% TBI severity: NR Time of assessment or since trauma: NR. Time since deployment was 35% 0–17 mos, 33% 18–35 mos, 33% 36 mos or greater Median age: 30 Women: 12% Race: white 66%; non-white 34% Education: NR Pain: NR Other mental health conditions: Probable major depression 14% | 6.6% of all subjects; 34% of TBI subjects (weighted percentages) | Self report, Brief Traumatic Brain Injury Screen. | Self report through PCL.-M.