# PEER REVIEWER COMMENTS

Reviewer Comments | Authors’ Responses
1. Are the objectives, scope, and methods for this review clearly described?
Strengthen review by using “history of TBI” and “sequelae of TBI” or “symptoms associated (or possibly associated) with history of TBI.” | Done.
Consider clarifying comorbid and comorbidity – maybe simpler to say that we meant PTSD in those with history of TBI or TBI in those who meet criteria for current PTSD. | We have defined and clarified our use of the terms “TBI,” “PTSD,” and “comorbidity” in the background section and throughout the revised report.
Use “other mental health conditions and anxiety disorders other than PTSD or anxiety symptoms unspecified” (PTSD is an anxiety disorder so use of terms “mental health comorbidities” and “anxiety” can be confusing at first read). | Changed statements throughout the revised report to read as recommended.
Add more rationale for focus on mTBI given the political context in which it takes place. | We have included a brief additional statement regarding the political importance and rationale for focusing on mTBI.
Explicitly state the reason for including the RAND study given that it is not peer-reviewed and not meeting inclusion criteria. Were other reports rejected? | A statement has been inserted. This study was peer reviewed. Though not published in a peer-reviewed journal, it is published by RAND and readily available on the RAND website. Additional rationale were provided in the draft report indicating that this was one of the largest and most nationally representative studies assessing TBI and PTSD in military personnel who had served in Iraq and Afghanistan. Therefore, it provides key evidence in examining TBI/PTSD prevalence.
We should be clear that this literature search is about people with a history of mTBI who are currently diagnosed with PTSD. | We have attempted to clarify this. Our search was broad. We included any study that assessed reported prevalence of individuals with mTBI and PTSD. Authors frequently referred to these individuals as having “comorbid” TBI and PTSD. However, we agree that the more accurate term for mTBI is “history of…” and have clarified this in our revised report.
Use Hoge review to clarify language – use post-concussive symptoms rather than TBI – for lasting symptoms that result from TBI; consider including paragraph about “language” or “terminology” at the beginning of the review. | We appreciate this suggestion and have been more clear throughout the report in terms of “TBI history,” “symptoms related to a TBI,” and “comorbidity.”
2. Is there any indication of bias in our synthesis of the evidence?
Inclusion of the RAND report without more justification may give impression of bias (note statement on pg. 30 that RAND report may provide the most reliable estimate …) – consider how study is weighted given that it is not peer reviewed; perhaps findings should be classified as secondary findings? | We have reworded the referenced statement on pg. 30 and provided further rationale for our inclusion of this report. As noted above, the RAND report includes a statement that it underwent peer review with multiple reviewers. The nature of comments and authors’ responses to these comments are not available. However, in our experience, the extent of peer review and number of reviewers on evidence reports (as witnessed by this VA ESP report) are typically greater than with most manuscripts submitted for publication in refereed journals. The final report is published on the RAND website. Whether it would have been accepted by a traditional paper journal is not known but we suspect condensed versions would have met journal publication criteria.
Some indication (in introduction) of belief that mTBI is associated with negative outcomes when this is the case in the minority of cases. | We have modified the introduction to include more information on the natural history of mTBI, including evidence that the majority of cases do not have long-term sequelae.
No; wondered why CH was a reviewer when he was a contributor with study; probably wanted unbiased reviewer; CH’s research is controversial as noted on pg. 2. | Reviewers frequently have a bias. Often our goal is to seek a selection of reviewers that will ensure a broad range of opinions and comments. Prior publication history does not disqualify a reviewer. In general, we select reviewers without disclosure of the names of other reviewers, including the TAP members.
3. Are there any studies on the epidemiology, assessment, or treatment of TBI/PTSD that we may have overlooked?
Suggest including Bryant study (Ref #83) in Exec. Summary (80% TBI subjects go on to develop PTSD). | The referenced study was included under secondary findings because it did not meet the study inclusion criteria (did not include participants with probable or diagnosed PTSD), which were developed a priori in consultation with our TAP. Consistent with previous ESP report formats, we did not include secondary findings in our Executive Summary.
Terrio et al. paper. | The suggested paper did not meet the study inclusion criteria (did not include data on probable or diagnosed PTSD).
Terrio (if PTSD). | We have updated our search through June, 2009. The following additional studies met inclusion criteria and were added to the evidence synthesis review: Brenner et al., 2009; Chalton et al., 2009; and Mora et al., 2009.
4. Additional comments
Question 1 re comorbid TBI and PTSD is flawed; TBI is acute injury event while PTSD requires symptoms and impairment existing for a defined period of time AFTER the traumatic event; it would be correct to ask how often a TBI injury event may precede the onset of PTSD and whether TBI is a risk factor for PTSD; association may or may not be causal; it also would be correct to ask about comorbidity between PTSD and the sequelae or persistent symptoms/impairment resulting from TBI injury event; need accepted and valid case definition of sequelae attributed to mTBI/concussion; need to examine how strong the evidence is for causal association between mTBI/concussion and persistent symptoms, sequelae, or impairment (see recent IOM report). | The questions addressed in this evidence synthesis review were developed with considerable input from the VA ESP and specifically our TAP, with the purpose of addressing key questions of clinical and health policy importance and to inform the work of a VA consensus conference on this topic. We agree with the reviewer that the term “comorbid TBI and PTSD” is problematic especially when referring to mTBI. We had discussed the controversy surrounding this issue in our Introduction, Discussion and Future Research Recommendations sections. We have reviewed and further clarified these issues in the revised report. We strongly believe, and included in both our oral presentation at the consensus conference and in this report, that future research is needed to address the issues described by the reviewer.
It is correct to ask about how PTSD may affect, mediate, or confound the expression of symptoms attributed to an mTBI/concussion event (see 2008 NEJM); requires case-definition for dependent variable under study (e.g., symptom sequelae). | We agree and have spoken to this in our Limitations and Future Research Recommendations sections.
Report incorrectly applies the term prevalence; prevalence cannot be determined using the current definitions; technically correct to present the prevalence of PTSD in study participant who had a history of TBI (should not use present tense – see Figure 3); never correct to present prevalence of PTSD in those with TBI since TBI definition refers to past injury event (see Figure 2); figure should show prevalence of comorbid PTSD and persistent symptoms/sequelae attributed to TBI; lack of clarity by not separating mTBI from moderate and severe TBI for Question 1; inconsistent with Questions 2 and 3. | We have clarified throughout the revised report our intent to examine the prevalence of PTSD in individuals with a history of TBI. Our background clarifies that we addressed TBI with an emphasis on mTBI. For KQ1, we sought to examine prevalence of PTSD in individuals with a history of mTBI versus moderate or severe TBI. As such, our figures denote (when authors provided such information) the prevalence of mTBI history separate from moderate or severe TBI. For KQ2 and KQ3, we sought to assess diagnostic accuracy and treatment effectiveness versus harms for adults specifically with mTBI history who have PTSD.
Questions 2 and 3 are flawed for the same reasons; the mTBI/concussion (past injury event) cannot (and should not) be the focus of diagnosis and treatment at time PTSD is diagnosed; questions would only be valid if asked about accuracy or diagnosis and treatment of sequelae of mTBI/concussion in presence of PTSD (with definition of sequelae) | We disagree.
Need consistent and accurate terminology in characterizing the sequelae attributed to concussion/mTBI; “post-concussive symptoms” encompasses the entire spectrum of physical, neurocognitive, and behavioral symptoms attributed to concussion/mTBI; need agreement on the nature of the symptoms – medical, functional somatic syndromes, or related conditions. | We agree and have clarified our wording throughout the report.
Report addresses questions that cannot be answered; questions are ill-conceived; need to first address limitations of current concussion/mTBI definition, derive valid case definition for sequelae attributed to concussion/mTBI, and broaden the focus beyond PTSD. | We agree that future research is needed to address limitations of current case definitions of mTBI. This has been discussed in the report. As noted above, we disagree that the key questions were ill-conceived.
Classification or designation of TBI as an event, diagnosis, sequelae confusing; suggest careful editing, defining of terms, and rephrasing/reframing of results to address these concerns. | We thank the reviewer and have edited the report to address these concerns.
- EXECUTIVE SUMMARY
Restate key questions in results section. | We attempted to follow a standard VA ESP report format and have not restated key questions in the results section of the Executive Summary. However, key questions are restated in the Results section of the main report.
8% cut-off for <18 years old unclear – need to state rationale (make change in full report also). | We have edited the report to reflect our 10% cut-off for children <18 years of age.
- INTRODUCTION/BACKGROUND
Acknowledge that symptoms associated with mTBI in civilian cases generally resolve within weeks to months (1^st^ paragraph of intro gives impression that mTBI is typically associated with negative outcomes). | We have edited this section to include evidence on the natural history of mTBI.
First sentence of 4^th^ paragraph in background is inaccurate (“making an accurate diagnosis …”); think what was meant was “determining etiology of presenting problems in individuals who have a history of TBI and PTSD”; paragraph gives impression that symptoms are needed for TBI diagnosis and that persistent symptoms are common in mTBI (suggest reworking). | We appreciate the reviewer’s suggestion and have reworked the referenced paragraph.
Research on usefulness of education for mTBI is limited to education within a relatively short time period post-injury. | We have edited the relevant paragraph to address this comment.
Page 5 second paragraph difficult to follow. | We have clarified this paragraph.
May want to include DoD/VA definition of TBI in addition to CDC definition (Policy Memo October 2007). | Because the operational definitions are similar, we have retained the CDC definition in the report.
Did it matter whether diagnosis of mTBI was first followed by PTSD? Does it matter where initial evaluation starts … mental health or neurology? | We noted in the report that the reported prevalence of TBI/PTSD was highly dependent on the construction of the cohort, method and timing of ascertainment, and definitions of disease/injury. The current literature is insufficient to determine whether timing of event/diagnosis influences outcomes or if there are clinically important differences according to where the initial evaluation starts.
Comparison chart (pg 3) – several items are controversial. | Unclear comment. We have included the chart as a direct extraction from a published article that we reference. We believe it is important for the reader to have a full range of information. We have included in the text some background on the controversies surrounding case definitions.
Page 4, nice discussion between screening measures and clinician confirmed diagnosis; also important to mention that VA TBI screening is symptomatic probable TBI (true incidence is difficult to ascertain because positive TBI should be designated as such with or without continued symptoms); VA/DoD report a positive TBI screen as a symptomatic positive patient with probable TBI. | We thank the reviewer and have included a statement about the VA/DOD screening.
- METHODS
Add special section outlining and addressing some of the issues CH raises. | We have added further information to the Discussion section. Our Future Research Recommendations section had previously discussed these issues.
- RESULTS
More interested in prevalence of PTSD in a particular group of veterans who have suffered TBI than the overall prevalence of comorbid PTSD and TBI in the overall sample. | We reported the findings according to our key questions where data were available from published evidence. We have included a separate figure presenting data on prevalence of PTSD specifically in veterans with a history of mTBI.
RAND study and additional 5 studies not published? If published, why not included with other studies/manuscripts? | See our comment above regarding our rationale for including the RAND study. There were 31 unique published studies and the RAND report included in the evidence review. The other 5 publications met inclusion criteria but described the same study population as one of the 31 “unique” studies.
Flow diagram (fig 1) – what does “probable TBI/PTSD not included” mean? (clarify or reword). | We have clarified this in the diagram. This meant that individuals with a probable history of TBI and/or probable PTSD (as defined in our Methods section) were not included in the study and thus the study did not meet our evidence report inclusion criteria.
Would like to see table of 28 included studies earlier, including study design, quality rating, and population studied (perhaps grouped by population studied as in Table 2); this would be more helpful than current Table 1. | We placed the table in the appendix consistent with the ESP report template. The quality ratings did not directly apply to these studies and we discussed issues regarding applicability.
Would like to see more description and summarization of the findings from higher quality or more relevant studies rather than limited information including ranges across all studies | We have attempted to do this through our emphasis on the RAND report. Relevant to the military and veteran population, this study was the most population-based as investigators attempted to contact a random sample of military veterans across the United States. Additionally, investigators used detailed, previously-established methods for conducting phone interviews. We disagree that providing ranges across studies is not helpful. These help to show the variation in the literature that may result from studies employing different methods for cohort creation, case ascertainment and timing, and definitions of disease/injury. Therefore it is instructive in establishing future research recommendations.
- ACTIVE RESEARCH
Did not identify any RCTs rather than state that there are none | We have edited accordingly.
More info on methods for Active Research – How many e-mails (effort to secure responses?); type of response from non-VA investigators; portfolio mgrs other than HSR&D? | A brief statement has been inserted. We acknowledge that our methods likely do not achieve rigorous scientific quality measures. This was an attempt to identify with limited resources high profile active research. The purpose was to guide policy makers, funders, and researchers to ongoing studies and assist in future research planning.
- FUTURE RESEARCH
Add to future research (pg 31) the need to review “systems issues” and coordination with different specialties – there is a real need to figure out ways to get the various specialties together to do treatment planning (Batten & Pollack, 2008 discuss this need). | We appreciate this suggestion and have added this suggestion to our Discussion.
Explicit recommendations that researchers come to a consensus as to measures to be used in this research so that findings can be pooled/compared more easily. | We agree with this suggestion and have clarified this section in our Discussion.
Don’t understand ascertainment bias; term “overlapping conditions” is confusing; don’t understand 1^st^ sentence of last paragraph (p 31). | We have attempted to clarify these parts of the Discussion section. Ascertainment bias refers to problems with how the cases were defined, identified, and enrolled in a given study that could systematically skew the association(s) under investigation. This could occur because of selection of non-representative study populations, non-representative study participants, timing of the case assessment relative to the injury event, or individuals being aware of the purpose of the assessment and potential gains/harms from a certain response. Each of these alone could potentially result in study outcomes that are biased and not truly reflective of the actual prevalence of TBI/PTSD.
- OVERALL
Overall, the manuscript is very well written. Thanks for doing this. | We thank the reviewers for their guidance and positive feedback.
I am impressed with this comprehensive report and I found the figures and tables very useful! | Thank you.