# DATA ABSTRACTION FORM

TBI/PTSD Review Article Abstraction Form