# SEARCH STRATEGY

Our study search coordinator, in consultation with our evidence synthesis team, developed the following search strategy. The PubMed and PsycINFO databases were searched for the following terms:

- TBI – brain injury (and variants of injury); coma; coma, post-head injury; Glasgow Coma Scale; head injuries, closed; post-concussion syndrome; brain concussion; post-concussive; and brain injury, chronic.
- PTSD - combat disorders (and variants of disorder); posttraumatic stress; posttraumatic stress disorder (and variants of disorder); post-traumatic stress disorder (and variants of disorder); stress disorders, post-traumatic; anxiety; and anxiety disorders.

The results from the TBI and PTSD searches were merged attempting to identify studies that included participants with both TBI and PTSD. The search was limited to English language studies of human subjects published between 1980 and 2009.

Sample Search Strategy:
1 | brain injur*.mp. or exp Brain Injuries
2 | coma.mp. or Coma, Post-Head Injury/or Coma/or Glasgow Coma Scale
3 | Head Injuries, Closed/or Post-Concussion Syndrome/or Brain Concussion/or post-concussive.mp. or Brain Injury, Chronic
4 | combat disord*.mp. or exp Combat Disorders
5 | (posttraumatic stress or posttraumatic stress disorder* or post-traumatic stress disorder* or ptsd).mp. or exp Stress Disorders, Post-Traumatic
6 | anxiety.mp. or exp Anxiety/or exp Anxiety Disorders
7 | or/1–3
8 | or/4–6
9 | 7 and 8
10 | limit 9 to English language
11 | limit 10 to yr=”1980 – 2009”
12 | limit 11 to human

In addition, the REHABDATA database was searched as follows:

From the advanced search page at www.naric.com/research/rehab/advanced.cfm,

Used “All the words” field,

Searched for “brain injuries posttraumatic.”

[Provided by Jessica Chaiken of the National Rehabilitation Information Center (NARIC)]

Results of the database searches were combined and duplicate entries eliminated.