# SUMMARY

Tai Chi has been investigated as a treatment for a number of clinical indications and outcomes. The systematic review of systematic reviews identified 107 Tai Chi systematic reviews. Reviews addressing general health effects, psychological wellbeing, or interventions in older adults included between 31 and 51 Tai Chi RCTs. The topic areas balance, hypertension, falls, quality of life, cognitive performance, and vestibulopathy have also been the focus of research; included reviews identified 10 or more pertinent RCTs per topic. Statistically significant effects pooled across existing studies were reported for hypertension, falls outside of institutions, cognitive performance, osteoarthritis, COPD, pain, balance confidence, depression, and muscle strength. However, review authors cautioned that firm conclusions cannot be drawn due to methodological limitations in the original studies and/or an insufficient number of existing research studies.

## ACKNOWLEDGEMENTS

We would like to thank Andrew Siroka for designing the bubble plot, Ning Fu for assistance with the data extraction, and Jeremy Miles for assistance with the data synthesis.