# RESULTS

The systematic review of systematic reviews identified 321 citations. This included 107 unique systematic reviews meeting the inclusion criteria.1,3-108 One potentially relevant publication could not be obtained for inclusion screening.109 The figure shows the number of included systematic reviews summarizing Tai Chi research by year.

Figure 1 English-language systematic reviews on Tai Chi published to February 2014

Most of the 107 included systematic reviews were published in the last 4 years with a current peak in 2013. The number of published systematic reviews is increasing, for example from 0 to 2 reviews published each year from 1999 to 2006 (excluding 2004) to 7 to 24 reviews published per year from 2007 onwards. The 2014 column is not informative because searches were performed in February and complete statistics for 2014 are not known. We excluded earlier versions of reviews and only retained the latest update of the systematic review in the dataset; however, excluded earlier versions had been published in the years 2008 to 2010, not earlier.

## EVIDENCE MAP OF TAI CHI

The results are presented in a bubble plot and a text summary. The bubble plot summarizes the results of all identified systematic reviews for distinct clinical indications.

Figure 2 Evidence Map of Tai Chi February 2014

The bubble plot summarizes Tai Chi systematic reviews published to February 2014 and depicts the clinical conditions addressed in reviews (bubbles), the estimated size of the literature (y-axis), the effectiveness trend according to reviews (x-axis), and the number of systematic reviews (bubble size) per clinical condition.

The evidence map used the clinical topics addressed in existing systematic reviews. Primary research studies may have contributed to more than one included systematic review. Studies included in the evidence map varied widely in the style of employed Tai Chi, the intervention duration, and intervention intensity, but none of the effects was primarily based on studies where Tai Chi was only a component of the overall intervention, or the effect was based on studies using a nontraditional format such as water-based Tai Chi. Of the included reviews, 58% did not address adverse events, 7% addressed adverse events but did not report on specific adverse events in the included studies, and 35% reported on the presence or absence of adverse events. All depicted dimensions in the bubble plot are estimates of the evidence base and can provide only a broad overview.

## EXECUTIVE SUMMARY

### Areas with the Largest Research Base

Most research, defined as clinical areas with at least 10 identified RCTs in the largest review, was included in general overviews that addressed general health benefits, psychological wellbeing, or the effect of Tai Chi in older adults. Six systematic reviews were identified that have addressed health benefits of Tai Chi10,15,31,50,55,74 and the largest review included 51 Tai Chi RCTs. The largest review, a comprehensive review of health benefits of qigong and Tai Chi, did not provide treatment effect estimates across individual studies but concluded that research has demonstrated consistent, significant results for a number of health benefits in RCTs, evidencing progress toward recognizing the similarity and equivalence of qigong and Tai Chi.50 Health benefits were also addressed in a 2007 AHRQ report on meditation practices which included 29 Tai Chi RCTs, in the majority rated poor quality.14 Results of individual studies and pooled results across clinical areas and outcomes varied. The other systematic reviews, addressing Tai Chi or movement therapy as a nursing intervention, effects of martial arts on health status, therapeutic benefits of Tai Chi, or Tai Chi Chuan as a mind-body practice or exercise intervention, primarily highlighted the need for more research. Five systematic reviews concentrated on psychological wellbeing1,19,27,51,106 and the largest included 37 RCTs. The largest review pooled only 3 of the included RCTs and reported positive effects of Tai Chi compared to wellness education and stretching for depression (mean difference [MD] -5.97, 95% confidence interval [CI] -7.06, -4.87).19 A meta-analysis reported positive pooled results for stress (Hedges' g 0.97; 95% CI 0.06, 1.87; 4 RCTs) and depression (Hedges' g 0.48; 95% CI 0.17, 0.78; 9 RCTs), but not anxiety or mood outcomes, associated with Tai Chi compared to a variety of comparators.1 A further review concluded it is premature to form conclusions on the effect of Tai Chi on psychological wellbeing. Two further reviews concluded psychological benefits without providing specific treatment estimates, but highlighted no superiority of Tai Chi compared to other low to moderate intensity activities. Four reviews addressed interventions in older adults80,81,90,108 and the largest included 31 RCTs. Three of the reviews did not target particular outcomes; instead they reviewed clinical trials of Tai Chi and qigong in older adults (defined as older than 55), perceived benefits of meditative movements in older adults (defined as older than 65), or the efficacy of Tai Chi Chuan in older adults (defined as older than 50). One review addressed exercise and mental well-being in older adults (defined as 65 or older). The largest review combined Tai Chi and qigong81; none of the reviews reported specific treatment effects of Tai Chi across studies.

The outcome balance has been addressed in 9 systematic reviews by independent author groups4,32,34,48,52,57,68,73,104 and the largest included 27 RCTs. The largest review concluded that studies appear to confirm that Tai Chi improves static and dynamic balance but did not provide specific treatment effect estimates.52 A Cochrane review on exercise interventions for improving balance in older people included 12 Tai Chi RCTs; individual study results varied and pooled results were only reported for a combination of Tai Chi, Gi Gong, dance, and yoga interventions studies.48 One review pooled 3 RCTs and found no effect of Tai Chi on the Single Leg Stance test compared to different control groups.4 Results of studies included in the remaining reviews varied and none of the reviews provided a treatment effect estimate across identified studies.

The outcome hypertension has been addressed in 3 systematic reviews64,92,101 and the largest included 18 RCTs. The largest review (published in 2013) reported statistically significant effects in favor of Tai Chi compared to routine care for a combined effectiveness outcome in lowering blood pressure (relative risk [RR] 3.39; CI 1.81, 6.34; 4 RCTs), systolic (weighted mean difference [WMD] -12.43; CI -1262, -12.24; 10 RCTs), and diastolic blood pressure (WMD -6.03; CI 6.16, -5.90; 10 RCTs), but the review cautioned that due to poor methodological quality, the evidence remains weak. A 2010 review that included 4 RCTs concluded the evidence for Tai Chi in reducing blood pressure in the elderly is limited64 and the other review did not provided pooled treatment estimates across studies due to study heterogeneity. Tai Chi in fall prevention using unselected studies or populations living in the community has been addressed in 10 independent reviews11,14,38,40,42,43,46,69,71,83,96 and the largest included 15 RCTs. The largest review reported no benefit of Tai Chi compared to non-exercise controls across 5 studies but a significant pooled estimate for Tai Chi versus exercise controls (incidence rate ratio [IRR] 0.51; 95% CI 0.38, 0.68; 2 RCTs).69 A Cochrane review on interventions for preventing falls in older people living in the community found no reduction in the rate of falls across 5 RCTs but a significantly reduced risk of falling (RR 0.71; 95% CI 0.57, 0.87; 6 RCTs) associated with Tai Chi compared to diverse, predominantly passive comparators (eg, wellness education).42 An AHRQ report on interventions to prevent falls in older adults included 3 Tai Chi studies but results were inconsistent and no pooled effect was reported.14 A systematic review on fall prevention that included 6 Tai Chi RCTs gave the pooled estimate for community dwelling studies as RR 0.66 (95% CI 0.52, 0.78; comparators not specified) but found no effect for residential aged-care facility studies.11 One review found no Tai Chi fall prevention study in older persons with cognitive impairment; the remaining reviews showed conflicting results across studies and did not provide a pooled effect estimate. Some reviews primarily addressing balance also reported on the outcome falls. One of these pooled the available data on falls and found no statistically significant results for Tai Chi.4

A systematic review that specifically addressed the outcome health-related quality of life across Traditional Chinese Medicine interventions included 15 Tai Chi RCTs.23 The review did not provide a summary estimate for Tai Chi effects and individual study results varied within and across studies. The outcome was also assessed in several other systematic reviews: positive effects were reported for patients with COPD99 and disease-specific quality of life in chronic heart failure patients;103 conflicting results across outcomes and across studies were reported for patients with osteoarthritis of the knee59 and musculoskeletal pain conditions;44 and no superiority compared to control interventions was found for cancer 60,75 and diabetes care,18,61 as described below in more detail.

One systematic review addressed the effects of Tai Chi on cognitive performance in older adults and identified 11 relevant RCTs.95 The review found a large effect of Tai Chi in executive function in cognitively healthy adults compared to no intervention (Hedges' g 0.90; p=0.04; 4 RCTs), a moderate effect compared to exercise (Hedges' g 0.51; p=0.003; 2 RCTs), smaller but statistically significant effects of global cognitive function in cognitively impaired adults compared with nonintervention controls (Hedges' g 0.35; p=0.004; 4 RCTs) and other active interventions (Hedges' g 0.30; p=0.002; 4 RCTs), but cautioned that larger and methodologically sound trials with longer followup periods are needed before definitive conclusions can be drawn.

One systematic review was identified that addressed the role of Tai Chi in vestibulopathy and it included 10 RCTs addressing a variety of outcomes.94 None of the included studies were in patients with a diagnosis of vestibular disease and the review concluded that more research is needed into the mechanism whereby Tai Chi can remedy balance disorders.

### Areas with a Smaller Research Base

Fewer research studies (ie, fewer than 10 RCTs identified in existing systematic reviews) are available for a large number of addressed clinical indications and outcomes.

Eight systematic reviews have addressed osteoarthritis6,16,25,39,53,59,84,86,98,110 and the 2 largest reviews included 9 RCTs each. Of the 2 largest reviews, one reported positive effects of Tai Chi compared to different control groups on pain (standard mean difference [SMD] -0.79; 95% CI -1.19, -0.39; p<0.001; 6 RCTs), physical function (SMD -0.86; 95% CI -1.20, -0.52; p<0.001; 6 RCTs), and joint stiffness (SMD -0.53; 95% CI -0.99, -0.08; p=0.02; 6 RCTs), but the review cautioned that due to the small number of RCTs with a low risk of bias, the evidence that Tai Chi is effective in patients with osteoarthritis is limited.53 The other large review did not report a numerical pooled treatment effect estimate, but a review specific to functional aerobic capacity in lower limb osteoarthritis by the same author group found significant improvements associated with Tai Chi (effect size [ES] 0.66; 95% CI 0.23, 1.09; 3 RCTs; 6-minute walk test) compared to education or no intervention.25 An independent review reported significant positive short-term effects of Tai Chi compared to waitlist or attention control for pain intensity (SMD -0.72; 95% CI -1.00, -0.44; 5 RCTs), function (SMD -0.72; 95% CI -1.01, -0.44; 5 RCTs), stiffness (SMD -0.59; 95% CI -0.99, -0.19; 5 RCTs), and physical quality of life (SMD 0.88; 95% CI 0.42, 1.34; 2 RCTs), but not for mental quality of life or long-term effects for pain, physical function, and stiffness (2 RCTs per comparison). The review highlighted that all positive results represent short-term effects and high quality RCTs are needed to confirm the results.59 A further osteoarthritis review and meta-analysis reported statistically significant effects compared to different control groups for pain (SMD -0.45; 95% CI -0.70,-0.20; 7 RCTs), stiffness (SMD -0.31; 95% CI -0.60, -0.02; 5 RCTs), and physical function (SMD -0.61; 95% CI -0.85, -0.37; 5 RCTs) and concluded that 12-week Tai Chi should be included in rehabilitation programs but that the evidence may be limited by potential biases.98 Two reviews did not identify any eligible Tai Chi RCTs and the remaining reviews did not report treatment effects across individual studies.

Cardiovascular disease has been the topic in 2 systematic reviews; both included 9 RCTs each.13,100 Reviews addressed a number of conditions and risk factors. Individual study results varied across outcomes and clinical indications and both reviews concluded that further research is needed. One review addressed the role of Tai Chi in chronic conditions and included 9 RCTs.91 Results of individual studies varied and the review concluded that it is difficult to draw firm conclusions. Tai Chi in cancer care has been evaluated in 5 systematic reviews22,30,60,66,75 and the largest included 8 RCTs. The largest review found positive pooled effects for the outcome vitality (MD 1.56; 95% CI 0.60, 2.51; 2 RCTs) and mental health (MD 2.38; 95% CI 1.75, 3.01; 2 RCTs) compared to standard care or support group but not for the SF-36 quality of life domains physical functioning, bodily pain, role physical, general health, social functioning, or role emotional (2 RCTs per comparison).22 A Cochrane review of health-related quality of life for cancer survivors included one Tai Chi RCT and reported no statistically significant effects of Tai Chi compared to walking.75 A review on exercise interventions for cancer-related fatigue among adult cancer survivors included the same Tai Chi study; it did not report statistically significant effects on fatigue. One review found no statistically significant effects of Tai Chi compared to a walking exercise, psychosocial support, or spiritual growth and standard health care on quality of life across 3 studies and concluded that the existing trial evidence does not show convincingly that Tai Chi is effective for supportive breast cancer care.60 The author group came to the same conclusion in a review on adjunct cancer care not limited to breast cancer.66

Tai Chi in type 2 diabetes has been addressed in 3 systematic reviews18,20,61 and the largest included 8 RCTs. The largest review meta-analyzed fasting blood glucose, glycosylated hemoglobin A1c, and quality of life (various comparators) and concluded that the existing evidence does not suggest that Tai Chi is an effective therapy for type 2 diabetes.61 A more recent systematic review (published in 2013) included 4 RCTs and also did not find statistically significant effects across studies on fasting blood glucose, hemoglobin A1c, and insulin resistance (compared to aerobic exercises, free activity program, waitlist, or sham exercise), and concluded a lack of Tai Chi related effects in patients with type 2 diabetes.20 A review on effects of exercise on quality of life, depression, anxiety, and emotional well-being in type 2 diabetes included 2 Tai Chi RCTs; both were included in the 2013 review and reported no significant between-group differences.18

Two systematic reviews have investigated Tai Chi for chronic obstructive pulmonary disease (COPD)37,99 and the largest included 8 RCTs. The largest review reported significant pooled effects of Tai Chi on the 6-minute walk test (WMD 34.22 m; 95% CI 21.25, 47.20; 3 RCTs), dyspnea (WMD –0.86 units; 95% CI –1.44, –0.28, 3 RCTs), forced expiratory volume in 1 second (FEV1; WMD 70 ml; 95% CI 0.02, 0.13, 4 RCTs), forced vital capacity (FVC; WMD 120 ml; 95% CI 0.00, 0.23, 3 RCTs), and 2 quality of life measures (WMD 0.95; 95% CI 0.22, 1.67; 2 RCTs; WMD -4.08; 95% CI -7.52, -0.64; 3 RCTs); the control intervention was not specified.99 The second review combined Tai Chi and qigong interventions and did not provide treatment estimates across Tai Chi studies. A review on asthma and COPD (described further below) included 4 RCTs but did not report a pooled treatment estimate. Four systematic reviews have focused on the outcome pain44,77,102,107 and the largest review included 7 RCTs including 6 arthritis studies. The largest review found a positive effect of Tai Chi on self-reported pain (MD 10.1 points on a 0-100 scale; 95% CI 6.3, 13.9; 6 RCTs; comparators not specified). The review also found a positive effect on self-reported disability (MD -9.6; 95% CI -14, -5.2; 4 RCTs) but not physical performance, and data for quality of life were not pooled across studies.44 Results of individual studies included in 2 other reviews varied and no treatment estimate of Tai Chi was reported while one found no eligible Tai Chi RCT. The outcome pain was addressed in several included systematic reviews. Three reviews on osteoarthritis reported statistically significant effects on pain (SMD -0.45; 95% CI -0.70,-0.20; 7 RCTs;98 SMD -0.79; 95% CI -1.19, -0.39; 6 RCTs;53 SMD -0.72; 95% CI -1.00, -0.44; 5 RCTs59) but cautioned that the evidence base is limited and/or results are limited to short-term effects. The Cochrane review on rheumatoid arthritis did not find statistically significant differences in joint tenderness associated with Tai Chi across 2 studies.45

One systematic review analyzed the effect of Tai Chi on immunity and infections and included 7 RCTs.47 Results varied by outcome and the overall treatment effect was not reported. Three reviews focused on heart disease35,78,103 and the largest included 7 RCTs. There was little overlap between studies included in the general cardiovascular disease reviews and those contributing to the heart disease-specific reviews. Two of the heart disease reviews reported conflicting results regarding the effectiveness of Tai Chi in included studies and did not provide an overall treatment effect estimate. The third review reported no reduction in N-terminal pro brain natriuretic peptide, systolic blood pressure, diastolic blood pressure, improved 6-minute walk test, or peak oxygen uptake but reported statistically significant results for quality of life in chronic heart failure patients (WMD -14.54, 95% CI -23.45, -5.63; 3 RCTs).

Five systematic reviews focused on the outcome balance confidence or fear of falling9,12,28,79,87 and the largest included 6 RCTs. The largest review did not report a treatment effect estimate across studies.9 A further review that included 5 Tai Chi RCTs among other interventions reported a positive pooled effect on balance confidence for Tai Chi compared to usual care, exercise, or education (SMD 0.47; 95% CI 0.30, 0.63; 4 RCTs).79 Two other systematic reviews on balance confidence and fear of falling included Tai Chi studies and concluded that Tai Chi seems beneficial but did not provide a treatment estimate across studies. One review on the impact of fear of falling in long-term care included a Tai Chi study; fear of falling, operationalized as a one-item question, did not differ across groups.

A systematic review on cystic fibrosis included 6 Tai Chi RCTs.70 Individual study results varied and no conclusions regarding an overall treatment effect of Tai Chi was reported. The role of Tai Chi in Parkinson's disease has been addressed in 2 independent reviews17,62 and the largest included 5 RCTs. Both reviews did not report an overall treatment effect and concluded that the evidence is insufficient to suggest Tai Chi is an effective intervention for Parkinson's disease. Two systematic reviews have addressed osteoporosis67,93 and the largest review included 5 RCTs. Results of individual studies included in the largest review varied by study and outcome; the only pooled estimate (bone mineral density at the spine, 4 RCTs) indicated no effect compared to no treatment in postmenopausal women.67 An earlier systematic review that included 2 RCTs concluded that Tai Chi may be effective but no treatment effect estimates were reported. One review addressed stroke rehabilitation and identified 5 RCTs.111 No meta-analysis was performed due to heterogeneity of conditions and outcomes and individual study results varied. One review summarized cardiopulmonary physiotherapeutic applications of Tai Chi and identified 5 relevant RCTs.56 The review did not report treatment effect estimates.

Two reviews investigated the effects of Tai Chi on aerobic capacity63,88 and the largest review included 5 RCTs. Both reviews showed no significant effect on peak oxygen uptake or maximal oxygen consumption across studies and the largest review concluded that the existing evidence does not suggest that regular Tai Chi is an effective way of increasing aerobic capacity.63 Aerobic capacity was also addressed in 2 other reviews; a review in osteoarthritis patients selected the 6-minute walk test as a functional aerobic capacity test and found positive results 25; a review on heart disease patients did not find effects on the 6-minute walk test or peak oxygen uptake.103

Five systematic reviews have specifically addressed the effects of Tai Chi on the outcome depression:21,29,33,89,97 the largest review included 4 RCTs, and a review of psychological wellbeing included 9 RCTs reporting on depression. The largest depression-specific review (published in 2012) reported significantly reduced depression symptoms (SMD -0.27; 95% CI -0.52; -0.02; 4 RCTs) compared to waitlist control across studies in older adults but highlighted that further research is recommended with larger samples sizes, more clarity on trial design and the intervention, longer-term followup, and concomitant economic evaluations.33 The general overview on Tai Chi and psychological wellbeing also reported a positive effect on depression (Hedges' g 0.48; 95% CI 0.17, 0.78); this earlier review included 9 RCTs in total, which includes 3 of the 4 RCTs reviewed in the largest depression-specific review.1 The other depression-specific reviews included only one or two Tai Chi studies or did not distinguish effects attributable to Tai Chi. As previously described, one other psychological wellbeing review included a statistically significant positive result of Tai Chi for depression compared to wellness education and stretching (MD -5.97, 95% CI -7.06, -4.87; 3 RCTs).19

Rheumatoid arthritis has been addressed in 3 systematic reviews45,65,72 and the largest included 3 RCTs. The largest review is a Cochrane review but it has not been updated since 2004. It concluded that Tai Chi does not exacerbate symptoms and that there are benefits for lower extremity range of motion, but not for most outcomes of disease activity, including activities of daily living, tender and swollen joints, and patient global ratings.45 A second review included one, not statistically significant, RCT, and a further review found conflicting results across studies and concluded that collectively the evidence is not convincing enough to suggest that Tai Chi is an effective treatment for rheumatoid arthritis.65 Two reviews summarized evidence of Tai Chi effects on fibromyalgia58,76 and both included 2 RCTs. Both reviews reported results across meditative movement or complementary and alternative exercise interventions and did not provide summary treatment effect estimates for Tai Chi specifically or pooled results across a number of study designs. One review on insomnia included 2 Tai Chi RCTs.82 The review indicated that both trials were positive on a variety of Pittsburgh Sleep Quality Index measures but the statistical significance was not reported.

A systematic review on the effects of Tai Chi on lower-limb muscle strength in the elderly included 2 RCTs.5 Both RCTs showed positive effects but did not report on the same outcome and were not combined to estimate the overall treatment effect.

A Cochrane review on interventions for preventing falls in older people in care facilities and hospitals (falls-institutions) included 2 Tai Chi studies, both reporting no significant difference in risk of falling associated with Tai Chi.3 The result was also found by an independent review group.11 One review addressed the question of whether exercise interventions designed to prevent falls affect participation in life roles (life participation) and included 2 Tai Chi RCTs.40 Both included RCTs did not show statistically significant effects of Tai Chi compared to usual care.

A review on Tai Chi for asthma and COPD identified one RCT in patients with asthma.85 The study found improvements in forced vital capacity (p=0.019) after exercise and at rest (p=0.024), as well as improved forced expiratory volume (p=0.049) at rest; the control group was not specified. However, the included study was in children (outside the scope of this evidence map) and effects on adults are not known.

Two systematic reviews on menopause symptoms,7,49 and one systematic review each on multiple sclerosis,105 metabolic syndrome,24 PTSD,54 older adults with dementia,41 urinary incontinence stress in women,8 and anxiety during pregnancy (pregnancy-anxiety),26 searched for Tai Chi RCTs but did not identify any.

### Most promising areas

In high research volume areas, most promising results across existing reviews were documented for the research areas hypertension, fall prevention outside of institutions, and cognitive performance. However, reviews in all 3 topic areas stated reservations in the conclusions due to the poor quality of the included studies (hypertension, cognitive performance), or conflicting results across outcomes (risk of falling vs rate of falls), comparators (exercise vs non-exercise control groups), and settings (community vs hospitals and care homes).

Statistically significant health effects were also reported for osteoarthritis, COPD, pain, balance confidence, depression, and muscle strength. However, review authors cautioned that the existing evidence is based on insufficient numbers of RCTs and/or poor quality RCTs and is not well equipped to provide definitive answers on the effectiveness of Tai Chi for patient health outcomes.

### VA priority areas

The following provides more detail on the content areas of pain, PTSD, and fall prevention.

#### Pain

The outcome pain was the primary focus of 4 systematic reviews.44,77,102,107 Of the focused reviews, the largest one, published in 2009, identified 7 relevant RCTs. Although all chronic musculoskeletal pain conditions were eligible for inclusion, 6 of the identified studies were in patients with chronic arthritis (osteoarthritis of the hip, knee, lumbar spine, and/or ankle, and rheumatoid arthritis). The seventh included study targeted patients with chronic tension headaches. The individual studies tested Yang-, Sun-, and Wu-style Tai Chi practiced from one to 3 times per week. The intervention duration ranged from 6 to 15 weeks (median 12 weeks). This largest review found a positive effect of Tai Chi on self-reported pain using different assessment scales across studies (MD 10.1 points on a 0 to 100 numerical rating scale; 95% CI 6.3, 13.9; 6 RCTs; comparators not specified).44 It concluded that Tai Chi has a small positive effect on pain and disability in people with arthritis, but cautioned that the available data are sparse and derived principally from low-quality studies. The review did not address adverse events. A review on self-management strategies to reduce pain and improve function among older adults in community settings (published in 2008) cited the 2004 Cochrane review on rheumatoid arthritis45 and 2 additional RCTs in osteoarthritis of the knee or lower extremity osteoarthritis. The review indicated that one of the included studies reported a positive effect of Tai Chi compared to usual care (N=72, mean age 64, 12 weeks), while the other one did not (N=33, mean age 68, 12 weeks) and no overall treatment effect estimate was provided.102 The review did not address adverse events. A 2007 review on mind-body interventions for chronic pain in older adults included the same 2 Tai Chi RCTs and the synthesis focused on the potential of Tai Chi in preserving function in older adults.77 The review did not report on adverse events in included studies but concluded that the reviewed mind-body interventions are likely safe. One meta-analysis on core stability exercise versus general exercise for chronic low back pain did not identify any eligible Tai Chi RCTs although Tai Chi studies had been explicitly searched for.107

The outcome pain was addressed in 21 included systematic reviews.6,10,16,23,39,44,45,50,53,55,58,59,72,76,77,81,84,98,102,107 Summary estimates of the size of the effect of Tai Chi on pain across at least 2 RCTs were reported in 5 reviews, including the above discussed review with the primary outcome pain. A 2013 meta-analysis in osteoarthritis reported statistically significant and clinically important effects for pain (SMD -0.45; 95% CI -0.70,-0.20; 7 RCTs) across studies comparing Tai Chi to waiting list, Bingo, attention control programs, routine treatment, self-help programs, or wellness education and stretching.98 The intervention programs varied from 8 to 24 weeks practicing Tai Chi from oneto 3 times per week. A subgroup analysis showed significant effects on pain and physical function in studies of 12 weeks or fewer but not in studies of longer duration. The authors highlighted that the pain relieving effect is not sustained and that additional studies are needed to investigate the long-term effects of Tai Chi in patients with knee osteoarthritis. The review concluded that 12-week Tai Chi should be included in rehabilitation programs but that the evidence may be limited by potential biases. An earlier osteoarthritis review reported significant positive effects of Tai Chi on pain (SMD -0.79; 95% CI -1.19, -0.39; 6 RCTs). Studies evaluated Yang- or Sun-style Tai Chi, practiced in the majority twice a week (where specified), and the intervention duration ranged between 6 weeks and 6 months. The effects were larger in comparison to attention control groups (SMD -1.18; 95% CI -1.82, -0.54; 3 RCTs) than compared to routine care (SMD -47; 95% CI -0.79, -0.14; 3 RCTs); the followup period was not specified. The review cautioned that due to the small number of studies with a low risk of bias, the evidence that Tai Chi is effective in patients with osteoarthritis is limited.53 The Cochrane review on rheumatoid arthritis did not find statistically significant differences in joint tenderness associated with Tai Chi across 2 studies.45 A review specific to osteoarthritis of the knee reported significant short-term positive effects for pain intensity (SMD -0.72; 95% CI -1.00, -0.44); 5 RCTs) associated with Tai Chi but not long-term effects, based on 2 studies. The included interventions were described as Yang-style, Sun-style, Tai Chi Qigong, and 12-form Sun-style for arthritis. The weekly frequency of practice varied and the duration ranged from 8 to 48 weeks; some studies included exercises at home after formal instructions ended (instruction time ranged from 8 to 20 weeks). The review highlighted that all positive results represent short-term effects and high quality RCTs are needed to confirm the results.59

Of the 21 systematic reviews reporting on the outcome pain, 43% did not address adverse events. Of those reviews that addressed adverse events, one did not report on adverse events in included studies but stated that the analyzed self-management strategies, which included Tai Chi interventions, are not associated with adverse side effects.102 One review did not report on adverse events in included studies but stated that Tai Chi is likely safe and cited other reviews.77 Another review that included 2 Tai Chi RCTs stated a lack of adverse events but did not report on individual studies.76 A large review that included 77 qigong and Tai Chi studies stated that 9 monitored adverse events, and none of these studies reported adverse events.50 One review reported that 4 out of 9 included RCTs had assessed adverse events, none reported any serious events, 2 RCTs reported minor muscle soreness and foot and knee pain in the early days of the intervention, one RCT reported increased knee pain and 2 cancer occurrences unrelated to the intervention, and one RCT reported serious adverse events that were not related to the intervention.53 A review that included 5 Tai Chi RCTs reported that adverse events were assessed in 3 RCTs; 2 were the aforementioned adverse events, while one RCT reported that no adverse events occurred.59 A review reported that that only 3 out of 8 included Tai Chi RCTs reported safety data; among these, no significant adverse events were reported from participating in a Tai Chi program.16 One review that included 2 Tai Chi RCTs reported that no serious adverse events were reported.58 One review reported that no significant adverse events associated with Tai Chi were found.98 One review included only one Tai Chi RCT; no adverse events were observed in the study.72 One review addressed adverse events but did not include any Tai Chi RCTs.107

The 15 published RCTs currently indexed in PubMed that address the outcome pain in the title or abstract of the citation focused on Tai Chi effects in arthritis, fibromyalgia, immune function, chronic disease, osteopenia, back pain, and diabetes.112-126 RCTs were published between 2003 and 2013. It is difficult to reconstruct which RCTs would be included in the systematic reviews presented above and whether the pooled results of the meta-analyses would consequently change if the reviews were updated today. The RCTs, including the larger ones with 100 or more participants, 114-118,121 show conflicting results for the effectiveness of Tai Chi compared to diverse control groups.

#### PTSD

The effects of Tai Chi on PTSD, the second VA priority area, have not been rigorously studied. The earlier described systematic review on mind-body practices for PTSD had searched the databases PubMed/MEDLINE, EBSCO/PsycINFO, and the Published International Literature on Traumatic Stress database in June 2012 for peer-reviewed original journal articles in English evaluating Tai Chi interventions. The review identified one relevant Tai Chi study.54 The included study was an uncontrolled case series reporting on 4 refugee survivors of torture that had received 10 to 15 minutes of simplified qigong and Tai Chi sessions prior and after psychotherapy sessions.127 The participants reported looking forward to the sessions and finding them calming and relaxing. The sessions were found to facilitate subsequent psychotherapy sessions, with a decrease in hypervigilance and an increase in introspection observed during psychotherapy. No adverse events or complications related to qigong or Tai Chi were reported.

No studies in combat-related PTSD were identified. The described review and the primary study remain the only citations in PubMed addressing Tai Chi and PTSD. A comprehensive search without language or date restriction in 5 additional databases did not find any additional empirical studies.

#### Fall Prevention

As shown, fall prevention was the focus of numerous included systematic reviews. Effects of Tai Chi in unselected studies or populations living in the community have been addressed in 10 independent reviews11,14,38,40,42,43,46,69,71,83,96 and the largest included 15 RCTs. As described above, this large 2010 review reported no statistically significant benefit of Tai Chi compared to non-exercise controls across 5 RCTs and found no changes in effects in subgroup analyses stratified by setting, intervention dose, and duration of followup. However, a significant pooled estimate on fall rates was found, favoring Tai Chi compared to exercise (IRR 0.51; 95% CI 0.38, 0.68; 2 RCTs).69 The 2 included RCTs evaluated Yang-style Tai Chi practiced 3 times a week. The authors speculated that the exercise control interventions in the 2 RCTs were possibly comparable with a placebo condition and refuted the interpretation that exercise increases the risk of falls. A Cochrane review on interventions for preventing falls in older people living in the community found no reduction in the rate of falls across 5 RCTs comparing Tai Chi to low level stretching, fall prevention brochure, waiting list, group discussions, or wellness education. However, the review found a significantly reduced risk of falling (RR 0.71; 95% CI 0.57, 0.87; 6 RCTs) associated with Tai Chi group exercises compared to low level stretching, fall prevention brochures, waiting list, wellness education and two not further specified comparators.42 The interventions were described as Tai Chi Chuan, modified Tai Chi, Sun-style Tai Chi, or Yang-style Tai Chi, practiced from 1 to 5 times per week across studies. The intervention duration ranged from 8 to 52 weeks. The rate of falls was defined as the total number of falls per unit of person time that occurred (eg, falls per person year). For risk of falling, the number of fallers was used and the risk ratio compared the number of people who fell once or more (fallers). The treatment effect was greater in the subgroup not selected for higher risk of falling, indicating that Tai Chi appears to be more effective in people who are not at high risk of falling. The AHRQ report on interventions to prevent falls in older adults included Tai Chi studies but did not report a pooled effect estimate.14 A systematic review on fall prevention that included 6 Tai Chi RCTs gave the pooled estimate for community dwelling studies as RR 0.66 (95% CI 0.52, 0.78) but found no effect of for residential aged-care facility studies.11 One review found no Tai Chi fall prevention studies of older persons with cognitive impairment; the remaining reviews showed conflicting results across studies and did not provide a pooled effect estimate. A Cochrane review on interventions for preventing falls in older people in care facilities and hospitals included 2 Tai Chi studies; both reported no significant difference in risk of falling.3 One systematic review specifically addressed effects of fall prevention interventions on depressive symptoms and fear of falling among the aged, not their effects on falls.87

The outcome falls was reviewed in 23 of the included systematic reviews.3,4,10,11,14,34,38,40,42,43,46,50,55,57,68,69,71,81,83,90,91,96,104 Summary estimates for the size of the treatment effect across more than one RCT were reported in 5 reviews. This included the 4 focused meta-analyses described above. In addition, a systematic review and meta-analysis on interventions to improve balance and reduce falls in older adults found no statistically significant results for Tai Chi comparing fall counts across 2 RCTs each, at different followup points.4

Of the 23 reviews that reported the outcome falls, 70% did not address adverse events (ie, did not report on the presence or absence of adverse events). Adverse events were a secondary outcome in 2 Cochrane reviews on interventions for preventing falls but in one review none of the 6 included Tai Chi RCTs reported on adverse events42; in the other, no complications of the intervention (such as sprains, strains, and adverse effects of vitamin D) were reported but the 2 Tai Chi studies were not addressed specifically.3 As discussed, in a general review that also targeted the outcome falls, only 9 of 77 included qigong and Tai Chi RCTs monitored adverse (these reported none).50 In a review of the effect of fall prevention exercise programs on fall induced injuries, 6 out of 17 included studies specifically reported the absence of adverse events; the review included 2 Tai Chi studies but did not specify which included studies assessed adverse events.38 A review on balance and falls highlighted that one study in participants aged 75 or older showed a negative result; after a 6-month weekly Tai Chi maintenance program, the loss of balance was not significantly changed but the base of support was significantly reduced, indicating a decreased postural stability (sensory organization test).104 An AHRQ report that included 3 Tai Chi RCTs examined adverse effects of interventions to reduce falls as one of its key questions and reported that one Tai Chi study found increased falls in the intervention group (not statistically significant).14 One review noted that among frail elderly, the risk to become a faller was significantly increased by the intervention. The review concluded that Tai Chi practice by older adults may only be effective in a more robust older population and may not benefit frail participants. No other adverse effects resulting from Tai Chi participation were identified. 43

The 14 published RCTs indexed in PubMed and referring to the outcome fall in the title or abstract of the publication addressed interventions designed for older and/or frail elderly, Parkinson's disease, or patients at risk for falls.128-141 Tai Chi was either the primary focus or only part of the intervention, and fall prevention was the primary focus of some of the studies while others addressed primarily balance improvements. RCTs were published between 1997 and 2013. For 5 of the RCTs129,131,135,136,141 the latest follow up data were published after the search date of the largest systematic review by Logghe (15 RCTs)69, the AHRQ report on interventions to prevent falls in older adults, and the economic evaluation of community and residential aged care falls prevention strategies11. Three of these131,135,136 were published after the last updates of the Cochrane reviews for preventing falls in older people living in the community42 and interventions for preventing falls in older people in care facilities and hospitals.3

## FUTURE RESEARCH

This broad overview of the evidence on Tai Chi concentrated on research on the clinical effectiveness of Tai Chi to improve patient outcomes. It did not consider more refined questions such as the effect of different styles of Tai Chi or the effect of the practitioner's training and skill level. There is some indication that the effectiveness of Tai Chi may depend on setting or patient characteristics as indicated by differential effects of fall prevention in community versus hospitals or nursing homes, as well as the intervention duration (short-term vs long-term), and the comparator (exercise vs non-exercise). The evidence map also indicated that adverse events have not been investigated systematically and is hindered by poor and inconsistent reporting of adverse events.142 A number of authors have indicated that more research on long-term effects is needed. In addition, across topic areas, reviews concluded that more rigorous research on the clinical effectiveness of Tai Chi is needed.

We identified a large number of clinical indications with unclear evidence. Some reviews included a large number of RCTs, but they addressed very broad topics such as health effects, psychological wellbeing, or interventions targeting older adults and it is likely that effects are outcome- and indication-specific. The outcome balance has also received a lot of research interest but we did not identify a meta-analysis estimating the overall treatment effect; individual study results vary and may be difficult to combine due to a large number of individual tests. The outcome quality of life has also been addressed in a substantial number of trials but no pooled effect estimate exists and effects need to be stratified by comparator given the diversity of the evidence base. Evidence on the role of Tai Chi in chronic conditions, cardiovascular disease, cancer care, heart disease, cystic fibrosis, infections, stoke rehabilitation, osteoporosis, Parkinson's disease, cardiopulmonary interventions, rheumatoid arthritis, fibromyalgia, and insomnia is very limited due to the small number of published studies. In addition, systematic reviews in menopause, dementia, metabolic syndrome, PTSD, urinary incontinence, multiple sclerosis, and anxiety during pregnancy applications specifically searched for Tai Chi studies, but no RCTs (ie, high level of evidence research studies) were identified.

### Ongoing Research

The literature search identified 5 Cochrane review protocols published in the last three years on hypertension,143 type 2 diabetes,144 COPD,145 primary prevention of cardiovascular disease,146 and improving recovery after stoke,147 indicating ongoing reviews.

A search of the international registry of systematic reviews PROSPERO identified 4 ongoing registered systematic reviews on Tai Chi: the effect of Tai Chi on hypertension (CRD42014009016), Tai Chi for patients with type 2 diabetes (CRD42014008950), Tai Chi for Parkinson's disease (CRD42013004989), and Tai chi for osteoarthritis (CRD42011001859).

A further 11 registered reviews indicated that Tai Chi interventions are eligible for inclusion in the review: effectiveness of treatment programs aimed at reducing substance misuse among women in prisons (CRD42014009484), supervised exercise on cancer-related fatigue in breast cancer survivors (CRD42014007223), complementary and alternative medicine for lumbar intervertebral disc herniation (CRD42013006876), traditional Chinese exercise for non-communicable diseases (CRD42013006474), physical activity and psychological coping strategies in the management of painful diabetic neuropathy (CRD42013006365), effects of supervised physical activity on cancer related fatigue (CRD42013005803), clinical effectiveness and cost-effectiveness of interventions to prevent postnatal depression (CRD42012003273), effectiveness of physical leisure time activities on glycemic control in adult patients with diabetes type 2 (CRD42012002967), effectiveness of physical leisure time activities on the older adult's physical functioning (CRD42011001571), effectiveness of rehabilitation on physical functioning and quality of life for adults with vertebral osteoporosis or osteopenia (CRD42012002381), and the relationship between the psychosocial impact of osteoarthritis and exercise (CRD42012002963).

## LIMITATIONS

Evidence maps are only a broad overview of the evidence base, indicating areas in which research has been conducted and where more research is needed. Included Tai Chi interventions varied greatly by Tai Chi style, intervention duration, and intervention intensity, and studies varied in their choice of comparator to estimate the effectiveness of Tai Chi. More specific results need targeted systematic reviews (addressing selected clinical indications and outcomes), and effect modifiers should be analyzed in meta-regressions designed to identify sources of heterogeneity. To inform policy and clinical decision making, additional implementation variables are likely to be needed in addition to this broad map of the evidence.