# REFERENCES

1 Wang C, Bannuru R, Ramel J, Kupelnick B, Scott T, Schmid CH. Tai Chi on psychological well-being: systematic review and meta-analysis. BMC complementary and alternative medicine. 2010;10:23. [pmid: 20492638].
2 NIH National Center for Complementary and Alternative medicine (NCCAM). http://nccam.nih.gov/health/taichi/introduction.htm. February 12, 2014.
3 Cameron ID, Murray GR, Gillespie LD, et al. Interventions for preventing falls in older people in nursing care facilities and hospitals. Art. No.: CD005465. The Cochrane database of systematic reviews. 2012;1(12).
4 Leung DP, Chan CK, Tsang HW, Tsang WW, Jones AY. Tai chi as an intervention to improve balance and reduce falls in older adults: A systematic and meta-analytical review. Alternative therapies in health and medicine. Jan-Feb. 2011;17(1):40-48. [pmid: 21614943].
5 Liu B, Liu ZH, Zhu HE, Mo JC, Cheng DH. Effects of tai chi on lower-limb myodynamia in the elderly people: a meta-analysis. Journal of traditional Chinese medicine = Chung i tsa chih ying wen pan / sponsored by All-China Association of Traditional Chinese Medicine, Academy of Traditional Chinese Medicine. Jun. 2011;31(2):141-146.
6 Uthman OA, van der Windt DA, Jordan JL, et al. Exercise for lower limb osteoarthritis: systematic review incorporating trial sequential analysis and network meta-analysis. BMJ-British Medical Journal. Sep. 2013:347.
7 Woods NF, Mitchell ES, Schnall JG, et al. Effects of mind-body therapies on symptom clusters during the menopausal transition. Climacteric. Feb. 2014;17(1):10-22. [pmid: 23937432].
8 Bo K, Herbert RD. There is not yet strong evidence that exercise regimens other than pelvic floor muscle training can reduce stress urinary incontinence in women: a systematic review. Journal of physiotherapy. Sep. 2013;59(3):159-168. [pmid: 23896331].
9 Bula CJ, Monod S, Hoskovec C, Rochat S. Interventions aiming at balance confidence improvement in older adults: an updated review. Gerontology. 2011;57(3):276-286. [pmid: 21042008].
10 Chen KM, Snyder M. A research-based use of Tai Chi/movement therapy as a nursing intervention. Journal of holistic nursing : official journal of the American Holistic Nurses' Association. Sep. 1999;17(3):267-279. [pmid: 10690069].
11 Church J, Goodall S, Norman R, Haas M. An economic evaluation of community and residential aged care falls prevention strategies in NSW. New South Wales public health bulletin. Jun. 2011;22(3-4):60-68. [pmid: 21632001].
12 Lach HW, Parsons JL. Impact of Fear of Falling in Long Term Care: An Integrative Review. Journal of the American Medical Directors Association. 2013;14(8):573-577. [pmid: 23602257].
13 Lee MS, Pittler MH, Taylor-Piliae RE, Ernst E. Tai chi for cardiovascular disease and its risk factors: a systematic review. Journal of Hypertension. 2007;25(9):1974-1975. [pmid: 17762664].
14 Michael YL, Lin JS, Whitlock EP, et al. Interventions to Prevent Falls in Older Adults: An Updated Systematic Review. Evidence Report No. 80. AHRQ Publication No. 11-05150-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. Dec. 2010.
15 Ospina MB, Bond K, Karkhaneh M, et al. Meditation practices for health: state of the research. Evidence report/technology assessment. 2007;(155):1-263. [pmid: 17764203].
16 Shengelia R, Parker SJ, Ballin M, George T, Reid MC. Complementary therapies for osteoarthritis: are they effective?. Pain management nursing : official journal of the American Society of Pain Management Nurses. Dec. 2013;14(4):e274-288. [pmid: 24315281].
17 Toh SFM. A Systematic Review on the Effectiveness of Tai Chi Exercise in Individuals with Parkinson's Disease from 2003 to 2013. Hong Kong Journal of Occupational Therapy. 2014.
18 van der Heijden MMP, van Dooren FEP, Pop VJM, Pouwer F. Effects of exercise training on quality of life, symptoms of depression, symptoms of anxiety and emotional well-being in type 2 diabetes mellitus: a systematic review. Diabetologia. Jun. 2013;56(6):1210-1225. [pmid: 23525683].
19 Wang F, Lee EK, Wu T, et al. The Effects of Tai Chi on Depression, Anxiety, and Psychological Well-Being: A Systematic Review and Meta-Analysis. International journal of behavioral medicine. Sep. 28. 2013.
20 Yan JH, Gu WJ, Pan L. Lack of evidence on Tai Chi-related effects in patients with type 2 diabetes mellitus: a meta-analysis. Experimental and clinical endocrinology & diabetes : official journal, German Society of Endocrinology [and] German Diabetes Association. May. 2013;121(5):266-271.
21 Yohannes Am, C S. Management of depression in older people with osteoarthritis: a systematic review. Aging and Mental Health. 2010;14(6).
22 Zeng Y, Luo T, Xie H, Huang M, Cheng ASK. Health benefits of qigong or tai chi for cancer patients: a systematic review and meta-analyses. Complementary therapies in medicine. 2014.
23 Zhang F, Kong LL, Zhang YY, Li SC. Evaluation of impact on health-related quality of life and cost effectiveness of Traditional Chinese Medicine: a systematic review of randomized clinical trials. Journal of alternative and complementary medicine (New York, N.Y.). Dec. 2012;18(12):1108-1120.
24 Anderson JG, Taylor AG. The metabolic syndrome and mind-body therapies: a systematic review. Journal of nutrition and metabolism. 2011;2011. 276419.
25 Escalante Y, Garcia-Hermoso A, Saavedra JM. Effects of exercise on functional aerobic capacity in lower limb osteoarthritis: a systematic review. Journal of science and medicine in sport / Sports Medicine Australia. May. 2011;14(3):190-198. [pmid: 21111676].
26 Marc I, Toureche N, Ernst E, et al. Mind-body interventions during pregnancy for preventing or treating women's anxiety. The Cochrane database of systematic reviews. 2011;(7). CD007559.
27 Wang WC, Zhang AL, Rasmussen B, et al. The effect of Tai Chi on psychosocial well-being: a systematic review of randomized controlled trials. Journal of acupuncture and meridian studies. Sep. 2009;2(3):171-181. [pmid: 20633489].
28 Zijlstra GA, van Haastregt JC, van Rossum E, van Eijk JT, Yardley L, Kempen GI. Interventions to reduce fear of falling in community-living older people: a systematic review. Journal of the American Geriatrics Society. Apr. 2007;55(4):603-615. [pmid: 17397441].
29 Bridle C, S K, P S, A NM, L SE. Effect of exercise on depression severity in older people: systematic review and meta-analysis of randomised controlled trials. British Journal of Psychiatry. 2012;201(3).
30 Brown Jc, H-M TB, P LS, P SM, F RA, J BT. Efficacy of exercise interventions in modulating cancer-related fatigue among adult cancer survivors: a meta-analysis. Cancer Epidemiology, Biomarkers and Prevention. 2011;20(1).
31 Bu B, Haijun H, Yong L, Chaohui Z, Xiaoyuan Y, Singh MF. Effects of martial arts on health status: a systematic review. Journal of evidence-based medicine. Nov. 2010;3(4):205-219. [pmid: 21349072].
32 Chan WW, Bartlett DJ. Effectiveness of Tai Chi as a therapeutic exercise in improving balance and postural control. Physical and Occupational Therapy in Geriatrics. 2000;17(3):1-22.
33 Chi I, Jordan-Marsh M, Guo M, Xie B, Bai Z. Tai chi and reduction of depressive symptoms for older adults: a meta-analysis of randomized trials. Geriatrics & gerontology international. Jan. 2013;13(1):3-12. [pmid: 22680972].
34 Conrad Wooton A. An integrative review of Tai Chi research: an alternative form of physical activity to improve balance and prevent falls in older adults (Provisional abstract). Orthopaedic Nursing. 2010;29(2):108-118. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12010004303/frame.html. [pmid: 20335770].
35 Dalusung-Angosta A. The impact of Tai Chi exercise on coronary heart disease: a systematic review. Journal of the American Academy of Nurse Practitioners. Jul. 2011;23(7):376-381. [pmid: 21696487].
36 Ding M. Tai Chi for stroke rehabilitation: a focused review. American journal of physical medicine & rehabilitation / Association of Academic Physiatrists. Dec. 2012;91(12):1091-1096. [pmid: 23064479].
37 Ding M, Zhang W, Li K, Chen X. Effectiveness of T'ai Chi and Qigong on Chronic Obstructive Pulmonary Disease: A Systematic Review and Meta-Analysis. Journal of alternative and complementary medicine (New York, N.Y.). Aug. 20. 2013.
38 El-Khoury F, Cassou B, Charles MA, Dargent-Molina P. The effect of fall prevention exercise programmes on fall induced injuries in community dwelling older adults: systematic review and meta-analysis of randomised controlled trials. BMJ-British Medical Journal. Oct. 2013:347.
39 Escalante Y, Saavedra JM, Garcia-Hermoso A, Silva AJ, Barbosa TM. Physical exercise and reduction of pain in adults with lower limb osteoarthritis: a systematic review. Journal of back and musculoskeletal rehabilitation. 2010;23(4):175-186. [pmid: 21079296].
40 Fairhall N, S C, C L, C ID. Do exercise interventions designed to prevent falls affect participation in life roles? A systematic review and meta-analysis. Age and ageing. 2011;40(6).
41 Forbes D, Thiessen EJ, Blake CM, Forbes SC, Forbes S. Exercise programs for people with dementia. The Cochrane database of systematic reviews. 2013;12. CD006489.
42 Gillespie LD, Robertson MC, Gillespie WJ, et al. Interventions for preventing falls in older people living in the community. The Cochrane database of systematic reviews. 2012;9. CD007146.
43 Gregory H, Watson MC. The effectiveness of Tai Chi as a fall prevention intervention for older adults: a systematic review (Structured abstract). International Journal of Health Promotion and Education. 2009;47(3):94-100. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12009109363/frame.html.
44 Hall A, Maher C, Latimer J, Ferreira M. The effectiveness of Tai Chi for chronic musculoskeletal pain conditions: a systematic review and meta-analysis. Arthritis and rheumatism. Jun. 15. 2009;61(6):717-724. [pmid: 19479696].
45 Han A, Robinson V, Judd M, Taixiang W, Wells G, Tugwell P. Tai chi for treating rheumatoid arthritis. The Cochrane database of systematic reviews. 2004;(3). CD004849.
46 Harling A, Simpson JP. A systematic review to determine the effectiveness of Tai Chi in reducing falls and fear of falling in older adults (Structured abstract). Physical Therapy Reviews. 2008;13(4):237-248. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12008107523/frame.html.
47 Ho RT, Wang CW, Ng SM, et al. The effect of t'ai chi exercise on immunity and infections: a systematic review of controlled trials. Journal of alternative and complementary medicine (New York, N.Y.). May. 2013;19(5):389-396.
48 Howe TE, Rochester L, Neil F, Skelton DA, Ballinger C. Exercise for improving balance in older people. The Cochrane database of systematic reviews. 2011;(11). CD004963.
49 Innes KE, Selfe TK, Vishnu A. Mind-body therapies for menopausal symptoms: a systematic review. Maturitas. Jun. 2010;66(2):135-149. [pmid: 20167444].
50 Jahnke R, Larkey L, Rogers C, Etnier J, Lin F. A comprehensive review of health benefits of qigong and tai chi. American journal of health promotion : AJHP. Jul-Aug. 2010;24(6):e1-e25. [pmid: 20594090].
51 Jimenez PJ, Melendez A, Albers U. Psychological effects of Tai Chi Chuan. Archives of gerontology and geriatrics. Sep-Oct. 2012;55(2):460-467. [pmid: 22386602].
52 Jimenez-Martin PJ, Melendez-Ortega A, Albers U, Schofield D. A review of Tai Chi Chuan and parameters related to balance. Eur. J. Integr. Med. Dec. 2013;5(6):469-475.
53 Kang JW, Lee MS, Posadzki P, Ernst E. T'ai chi for the treatment of osteoarthritis: a systematic review and meta-analysis. BMJ open. Jan. 1. 2011;1(1):e000035.
54 Kim SH, Schneider SM, Kravitz L, Mermier C, Burge MR. Mind-body practices for posttraumatic stress disorder. Journal of investigative medicine : the official publication of the American Federation for Clinical Research. Jun. 2013;61(5):827-834. [pmid: 23609463].
55 Klein PJ, Adams WD. Comprehensive therapeutic benefits of Taiji: a critical review. American journal of physical medicine & rehabilitation / Association of Academic Physiatrists. Sep. 2004;83(9):735-745. [pmid: 15314540].
56 Klein PT, Adams W. Cardiopulmonary physiotherapeutic applications of taiji (Structured abstract). Cardiopulmonary Physical Therapy. 2004;15(4):5-11. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12005005115/frame.html.
57 Komagata S, Newton R. The effectiveness of Tai Chi on improving balance in older adults: an evidence-based review (Provisional abstract). Journal of Geriatric Physical Therapy. 2003;26(2):9-16. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12003005448/frame.html.
58 Langhorst J, Klose P, Dobos GJ, Bernardy K, Hauser W. Efficacy and safety of meditative movement therapies in fibromyalgia syndrome: a systematic review and meta-analysis of randomized controlled trials. Rheumatology international. Jan. 2013;33(1):193-207. [pmid: 22350253].
59 Lauche R, Langhorst J, Dobos G, Cramer H. A systematic review and meta-analysis of Tai Chi for osteoarthritis of the knee. Complementary therapies in medicine. Aug. 2013;21(4):396-406. [pmid: 23876571].
60 Lee MS, Choi TY, Ernst E. Tai chi for breast cancer patients: a systematic review. Breast cancer research and treatment. Apr. 2010;120(2):309-316. [pmid: 20127280].
61 Lee MS, Choi TY, Lim HJ, Ernst E. Tai chi for management of type 2 diabetes mellitus: a systematic review. Chinese journal of integrative medicine. Oct. 2011;17(10):789-793. [pmid: 21805298].
62 Lee MS, Lam P, Ernst E. Effectiveness of tai chi for Parkinson's disease: a critical review. Parkinsonism & related disorders. Dec. 2008;14(8):589-594. [pmid: 18374620].
63 Lee MS, Lee EN, Ernst E. Is tai chi beneficial for improving aerobic capacity? A systematic review. British journal of sports medicine. Aug. 2009;43(8):569-573. [pmid: 19019905].
64 Lee MS, Lee EN, Kim JI, Ernst E. Tai chi for lowering resting blood pressure in the elderly: a systematic review. Journal of evaluation in clinical practice. Aug. 2010;16(4):818-824. [pmid: 20557410].
65 Lee MS, Pittler MH, Ernst E. Tai chi for rheumatoid arthritis: systematic review. Rheumatology (Oxford, England). Nov. 2007;46(11):1648-1651.
66 Lee MS, Pittler MH, Ernst E. Is Tai Chi an effective adjunct in cancer care? A systematic review of controlled clinical trials. Supportive care in cancer : official journal of the Multinational Association of Supportive Care in Cancer. Jun. 2007;15(6):597-601. [pmid: 17318592].
67 Lee MS, Pittler MH, Shin BC, Ernst E. Tai chi for osteoporosis: a systematic review. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. Feb. 2008;19(2):139-146.
68 Liu H, Frank A. Tai chi as a balance improvement exercise for older adults: a systematic review. Journal of geriatric physical therapy (2001). Jul-Sep. 2010;33(3):103-109. [pmid: 21155504].
69 Logghe IH, Verhagen AP, Rademaker AC, et al. The effects of Tai Chi on fall prevention, fear of falling and balance in older people: a meta-analysis. Preventive medicine. Sep-Oct. 2010;51(3-4):222-227. [pmid: 20558197].
70 Lorenc AB, Wang Y, Madge SL, Hu X, Mian AM, Robinson N. Meditative movement for respiratory function: a systematic review. Respiratory care. Jul. 23. 2013.
71 Low S, Ang LW, Goh KS, Chew SK. A systematic review of the effectiveness of Tai Chi on fall reduction among the elderly. Archives of gerontology and geriatrics. May-Jun. 2009;48(3):325-331. [pmid: 18420290].
72 Macfarlane GJ, Paudyal P, Doherty M, et al. A systematic review of evidence for the effectiveness of practitioner-based complementary and alternative therapies in the management of rheumatic diseases: rheumatoid arthritis. Rheumatology (Oxford, England). Sep. 2012;51(9):1707-1713.
73 Maciaszek J, Osinski W. The effects of Tai Chi on body balance in elderly people--a review of studies from the early 21st century. The American journal of Chinese medicine. 2010;38(2):219-229. [pmid: 20387220].
74 Mansky P, Sannes T, Wallerstedt D, et al. Tai chi chuan: mind-body practice or exercise intervention? Studying the benefit for cancer survivors (Structured abstract). Integrative Cancer Therapies. 2006;5(3):192-201. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12006002889/frame.html. [pmid: 16880423].
75 Mishra SI, Scherer RW, Geigle PM, et al. Exercise interventions on health-related quality of life for cancer survivors. The Cochrane database of systematic reviews. 2012;8. CD007566.
76 Mist SD, Firestone KA, Jones KD. Complementary and alternative exercise for fibromyalgia: a meta-analysis. Journal of pain research. 2013;6:247-260. [pmid: 23569397].
77 Morone NE, Greco CM. Mind-body interventions for chronic pain in older adults: a structured review. Pain medicine (Malden, Mass.). May-Jun. 2007;8(4):359-375.
78 Ng SM, Wang CW, Ho RT, et al. Tai chi exercise for patients with heart disease: a systematic review of controlled clinical trials. Alternative therapies in health and medicine. May-Jun. 2012;18(3):16-22. [pmid: 22875558].
79 Rand D, Miller WC, Yiu J, Eng JJ. Interventions for addressing low balance confidence in older adults: a systematic review and meta-analysis. Age and ageing. May. 2011;40(3):297-306. [pmid: 21508204].
80 Rogers C, Keller C, Larkey LK. Perceived benefits of meditative movement in older adults. Geriatric Nursing. 2010;31(1):37-51. [pmid: 20159352].
81 Rogers CE, Larkey LK, Keller C. A review of clinical trials of tai chi and qigong in older adults. Western journal of nursing research. Mar. 2009;31(2):245-279. [pmid: 19179544].
82 Sarris J, Byrne GJ. A systematic review of insomnia and complementary medicine. Sleep medicine reviews. Apr. 2011;15(2):99-106. [pmid: 20965131].
83 Schleicher MM, Wedam L, Wu G. Review of Tai Chi as an effective exercise on falls prevention in elderly. Research in sports medicine (Print). Jan. 2012;20(1):37-58. [pmid: 22242736].
84 Selfe TK, Innes KE. Mind-Body Therapies and Osteoarthritis of the Knee. Current rheumatology reviews. Nov. 1. 2009;5(4):204-211. [pmid: 21151770].
85 Sharma M, Haider T. Tai chi as an alternative and complementary therapy for patients with asthma and chronic obstructive pulmonary disease: A systematic review. Journal of Evidence-Based Complementary & Alternative Medicine S2- Complementary Health Practice Review. Jul. 2013. 2013;18(3):209-215.
86 Simic M, Hinman RS, Wrigley TV, Bennell KL, Hunt MA. Gait modification strategies for altering medial knee joint load: a systematic review. Arthritis care & research. Mar. 2011;63(3):405-426. [pmid: 20981808].
87 Sjosten N, Vaapio S, Kivela SL. The effects of fall prevention trials on depressive symptoms and fear of falling among the aged: a systematic review. Aging & mental health. Jan. 2008;12(1):30-46. [pmid: 18297477].
88 Taylor-Piliae RE. The effectiveness of Tai Chi exercise in improving aerobic capacity: an updated meta-analysis. Medicine and sport science. 2008;52:40-53. [pmid: 18487885].
89 Tsang HW, Chan EP, Cheung WM. Effects of mindful and non-mindful exercises on people with depression: a systematic review. The British journal of clinical psychology / the British Psychological Society. Sep. 2008;47(Pt 3):303-322. [pmid: 18237457].
90 Verhagen AP, Immink M, van der Meulen A, Bierma-Zeinstra SM. The efficacy of Tai Chi Chuan in older adults: a systematic review. Family practice. Feb. 2004;21(1):107-113. [pmid: 14760055].
91 Wang C, Collet JP, Lau J. The effect of Tai Chi on health outcomes in patients with chronic conditions: a systematic review. Archives of internal medicine. Mar. 8. 2004;164(5):493-501. [pmid: 15006825].
92 Wang J, Feng B, Yang X, et al. Tai chi for essential hypertension. Evidence-based complementary and alternative medicine : eCAM. 2013;2013:215254. [pmid: 23986780].
93 Wayne PM, Kiel DP, Krebs DE, et al. The effects of Tai Chi on bone mineral density in postmenopausal women: a systematic review. Archives of physical medicine and rehabilitation. May. 2007;88(5):673-680. [pmid: 17466739].
94 Wayne PM, Krebs DE, Wolf SL, et al. Can Tai Chi improve vestibulopathic postural control?. Archives of physical medicine and rehabilitation. Jan. 2004;85(1):142-152. [pmid: 14970982].
95 Wayne PM, Walsh JN, Taylor-Piliae RE, et al. Effect of Tai Chi on Cognitive Performance in Older Adults: Systematic Review and Meta-Analysis. Journal of the American Geriatrics Society. Jan. 2. 2014.
96 Winter H, W K, P NM. Falls prevention interventions for community-dwelling older persons with cognitive impairment: a systematic review. International Psychogeriatrics. 2013;25(2).
97 Woltz PC, Chapa DW, Friedmann E, Son H, Akintade B, Thomas SA. Effects of interventions on depression in heart failure: a systematic review. Heart & lung : the journal of critical care. Sep-Oct. 2012;41(5):469-483. [pmid: 22938627].
98 Yan JH, Gu WJ, Sun J, Zhang WX, Li BW, Pan L. Efficacy of Tai Chi on pain, stiffness and function in patients with osteoarthritis: a meta-analysis. PloS one. 2013;8(4):e61672. [pmid: 23620778].
99 Yan JH, Guo YZ, Yao HM, Pan L. Effects of Tai Chi in patients with chronic obstructive pulmonary disease: preliminary evidence. PloS one. 2013;8(4):e61806. [pmid: 23626732].
100 Yeh GY, Wang C, Wayne PM, Phillips R. Tai chi exercise for patients with cardiovascular conditions and risk factors: A SYSTEMATIC REVIEW. Journal of cardiopulmonary rehabilitation and prevention. May-Jun. 2009;29(3):152-160. [pmid: 19471133].
101 Yeh GY, Wang C, Wayne PM, Phillips RS. The effect of tai chi exercise on blood pressure: a systematic review. Preventive cardiology. Spring. 2008;11(2):82-89. [pmid: 18401235].
102 Reid MC, Papaleontiou M, Ong A, Breckman R, Wethington E, Pillemer K. Self-management strategies to reduce pain and improve function among older adults in community settings: a review of the evidence. Pain medicine (Malden, Mass.). May-Jun. 2008;9(4):409-424.
103 Pan L, Yan J, Guo Y, Yan J. Effects of Tai Chi training on exercise capacity and quality of life in patients with chronic heart failure: a meta-analysis. European journal of heart failure. Mar. 2013;15(3):316-323. [pmid: 23099355].
104 Wu G. Progress in geriatrics Evaluation of the effectiveness of Tai Chi for improving balance and preventing falls in the older population -- a review. Journal of the American Geriatrics Society. 2002;50(4):746-754. [pmid: 11982679].
105 Binns EE, Taylor D. Does Tai Chi improve strength and balance in people with multiple sclerosis -- the current literature. New Zealand Journal of Physiotherapy. 2008;36(2):83.
106 Dechamps A, Lafont L, Bourdel-Marchasson I. Effects of Tai Chi exercises on self-efficacy and psychological health. Eur Rev Aging Phys Act. 2007;4(1):25-32.
107 Wang XQ, Zheng JJ, Yu ZW, et al. A meta-analysis of core stability exercise versus general exercise for chronic low back pain. PloS one. 2012;7(12):e52082. [pmid: 23284879].
108 Windle G, Hughes D, Linck P, Russell I, Woods B. Is exercise effective in promoting mental well-being in older age? A systematic review. Aging & mental health. 2010;14(6):652-669. [pmid: 20686977].
109 Hayes, Inc. Tai chi for improving balance and function in patients with parkinson's disease (Structured abstract). Health Technology Assessment Database. 2013;(1). http://onlinelibrary.wiley.com/o/cochrane/clhta/articles/HTA-32013000586/frame.html.
110 Lee MS, Pittler MH, Ernst E. Tai chi for osteoarthritis: a systematic review. Clinical rheumatology. Feb. 2008;27(2):211-218. [pmid: 17874172].
111 Fouladbakhsh J. Complementary and Alternative Modalities to Relieve Osteoarthritis Symptoms: A review of the evidence on several therapies often used for osteoarthritis management Reprinted with permission from American Journal of Nursing, 112(3), S44-S51, 2012. Orthopaedic Nursing. 2012;31(2):115-121. [pmid: 22446805].
112 Brismee JM, Paige RL, Chyu MC, et al. Group and home-based tai chi in elderly subjects with knee osteoarthritis: a randomized controlled trial. Clin Rehabil. Feb. 2007;21(2):99-111. [pmid: 17264104].
113 Chyu MC, James CR, Sawyer SF, et al. Effects of tai chi exercise on posturography, gait, physical function and quality of life in postmenopausal women with osteopaenia: a randomized clinical study. Clin Rehabil. Dec. 2010;24(12):1080-1090. [pmid: 20702512].
114 Fransen M, Nairn L, Winstanley J, Lam P, Edmonds J. Physical activity for osteoarthritis management: a randomized controlled clinical trial evaluating hydrotherapy or Tai Chi classes. Arthritis and rheumatism. Apr. 15. 2007;57(3):407-414. [pmid: 17443749].
115 Hall AM, Maher CG, Lam P, Ferreira M, Latimer J. Tai chi exercise for treatment of pain and disability in people with persistent low back pain: a randomized controlled trial. Arthritis care & research. Nov. 2011;63(11):1576-1583. [pmid: 22034119].
116 Hammond A, Freeman K. Community patient education and exercise for people with fibromyalgia: a parallel group randomized controlled trial. Clin Rehabil. Oct. 2006;20(10):835-846. [pmid: 17008336].
117 Irwin MR, Olmstead R, Oxman MN. Augmenting immune responses to varicella zoster virus in older adults: a randomized, controlled trial of Tai Chi. Journal of the American Geriatrics Society. Apr. 2007;55(4):511-517. [pmid: 17397428].
118 Jones KD, Sherman CA, Mist SD, Carson JW, Bennett RM, Li F. A randomized controlled trial of 8-form Tai chi improves symptoms and functional mobility in fibromyalgia patients. Clinical rheumatology. Aug. 2012;31(8):1205-1214. [pmid: 22581278].
119 Liu X, Miller YD, Burton NW, Chang JH, Brown WJ. The effect of Tai Chi on health-related quality of life in people with elevated blood glucose or diabetes: a randomized controlled trial. Qual Life Res. Sep. 2013;22(7):1783-1786. [pmid: 23143590].
120 Ni GX, Song L, Yu B, Huang CH, Lin JH. Tai chi improves physical function in older Chinese women with knee osteoarthritis. J Clin Rheumatol. Mar. 2010;16(2):64-67. [pmid: 20130482].
121 Siu AM, Chan CC, Poon PK, Chui DY, Chan SC. Evaluation of the chronic disease self-management program in a Chinese population. Patient Educ Couns. Jan. 2007;65(1):42-50. [pmid: 16872789].
122 Song R, Lee EO, Lam P, Bae SC. Effects of tai chi exercise on pain, balance, muscle strength, and perceived difficulties in physical functioning in older women with osteoarthritis: a randomized clinical trial. J Rheumatol. Sep. 2003;30(9):2039-2044. [pmid: 12966613].
123 Song R, Lee EO, Lam P, Bae SC. Effects of a Sun-style Tai Chi exercise on arthritic symptoms, motivation and the performance of health behaviors in women with osteoarthritis. Taehan Kanho Hakhoe Chi. Mar. 2007;37(2):249-256. [pmid: 17435410].
124 Tsai PF, Chang JY, Beck C, Kuo YF, Keefe FJ. A pilot cluster-randomized trial of a 20-week Tai Chi program in elders with cognitive impairment and osteoarthritic knee: effects on pain and other health outcomes. J Pain Symptom Manage. Apr. 2013;45(4):660-669. [pmid: 23017610].
125 Wang C, Schmid CH, Hibberd PL, et al. Tai Chi is effective in treating knee osteoarthritis: a randomized controlled trial. Arthritis and rheumatism. Nov. 15. 2009;61(11):1545-1553. [pmid: 19877092].
126 Wang C. Tai Chi improves pain and functional status in adults with rheumatoid arthritis: results of a pilot single-blinded randomized controlled trial. Medicine and sport science. 2008;52:218-229. [pmid: 18487901].
127 Grodin MA, Piwowarczyk L, Fulker D, Bazazi AR, Saper RB. Treating survivors of torture and refugee trauma: a preliminary case series using qigong and t'ai chi. Journal of alternative and complementary medicine (New York, N.Y.). Sep. 2008;14(7):801-806.
128 Faber MJ, Bosscher RJ, Chin APMJ, van Wieringen PC. Effects of exercise programs on falls and mobility in frail and pre-frail older adults: A multicenter randomized controlled trial. Archives of physical medicine and rehabilitation. Jul. 2006;87(7):885-896. [pmid: 16813773].
129 Huang HC, Liu CY, Huang YT, Kernohan WG. Community-based interventions to reduce falls among older adults in Taiwan - long time follow-up randomised controlled study. J Clin Nurs. Apr. 2010;19(7-8):959-968. [pmid: 20492040].
130 Li F, Harmer P, Fisher KJ, et al. Tai Chi and fall reductions in older adults: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. Feb. 2005;60(2):187-194. [pmid: 15814861].
131 Li F, Harmer P, Fitzgerald K, et al. Tai chi and postural stability in patients with Parkinson's disease. N Engl J Med. Feb. 9. 2012;366(6):511-519. [pmid: 22316445].
132 Logghe IH, Zeeuwe PE, Verhagen AP, et al. Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. Journal of the American Geriatrics Society. Jan. 2009;57(1):70-75. [pmid: 19054193].
133 Nowalk MP, Prendergast JM, Bayles CM, D'Amico FJ, Colvin GC. A randomized trial of exercise programs among older individuals living in two long-term care facilities: the FallsFREE program. Journal of the American Geriatrics Society. Jul. 2001;49(7):859-865. [pmid: 11527475].
134 Sattin RW, Easley KA, Wolf SL, Chen Y, Kutner MH. Reduction in fear of falling through intense tai chi exercise training in older, transitionally frail adults. Journal of the American Geriatrics Society. Jul. 2005;53(7):1168-1178. [pmid: 16108935].
135 Taylor D, Hale L, Schluter P, et al. Effectiveness of tai chi as a community-based falls prevention intervention: a randomized controlled trial. Journal of the American Geriatrics Society. May. 2012;60(5):841-848. [pmid: 22587850].
136 Tousignant M, Corriveau H, Roy PM, Desrosiers J, Dubuc N, Hebert R. Efficacy of supervised Tai Chi exercises versus conventional physical therapy exercises in fall prevention for frail older adults: a randomized controlled trial. Disabil Rehabil. Aug. 2013;35(17):1429-1435. [pmid: 23167499].
137 Voukelatos A, Cumming RG, Lord SR, Rissel C. A randomized, controlled trial of tai chi for the prevention of falls: the Central Sydney tai chi trial. Journal of the American Geriatrics Society. Aug. 2007;55(8):1185-1191. [pmid: 17661956].
138 Wolf SL, Barnhart HX, Ellison GL, Coogler CE. The effect of Tai Chi Quan and computerized balance training on postural stability in older subjects. Atlanta FICSIT Group. Frailty and Injuries: Cooperative Studies on Intervention Techniques. Phys Ther. Apr. 1997;77(4):371-381. discussion 382-374. [pmid: 9105340].
139 Wolf SL, O'Grady M, Easley KA, Guo Y, Kressig RW, Kutner M. The influence of intense Tai Chi training on physical performance and hemodynamic outcomes in transitionally frail, older adults. J Gerontol A Biol Sci Med Sci. Feb. 2006;61(2):184-189. [pmid: 16510864].
140 Woo J, Hong A, Lau E, Lynn H. A randomised controlled trial of Tai Chi and resistance exercise on bone health, muscle strength and balance in community-living elderly people. Age and ageing. May. 2007;36(3):262-268. [pmid: 17356003].
141 Wu G, Keyes L, Callas P, Ren X, Bookchin B. Comparison of telecommunication, community, and home-based Tai Chi exercise programs on compliance and effectiveness in elders at risk for falls. Archives of physical medicine and rehabilitation. Jun. 2010;91(6):849-856. [pmid: 20510973].
142 Wayne PM, Berkowitz DL, Litrownik DE, Buring JE, Yeh GY. What Do We Really Know About the Safety of Tai Chi?: A Systematic Review of Adverse Event Reports in Randomized Trials. Archives of physical medicine and rehabilitation. May. 27. 2014.
143 Wang Y, Shang H, Guo Y, Wu T, Tian L, Zhang J, Wang W. Tai Chi for hypertension. Cochrane Database of Systematic Reviews: Reviews. 2011;(10).
144 Zhou J, Zhang L, Liu H, Mallampati T, Xu M, Yang J. Tai Chi for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: Reviews. 2012;(3).
145 Ngai SPC, Jones AY, Tam W. Tai Chi for chronic obstructive pulmonary disease (COPD). Cochrane Database of Systematic Reviews: Reviews. 2012;(7).
146 Hartley L, Flowers N, Ernst E, Rees K. Tai chi for primary prevention of cardiovascular disease. 22/11/2013. 2013.
147 Xu C, Zhang HW, Leung AWN, Lin ZX, Qin Y. Tai Chi for improving recovery after stroke. Cochrane Database of Systematic Reviews: Reviews. 2012;(12).