# EVIDENCE MAP OF TAI CHI

## ABSTRACT

This evidence map provides an overview of Tai Chi research and describes its volume and focus. It combines a systematic review of systematic reviews with a scoping review for the VA priority areas pain, posttraumatic stress disorder, and fall prevention. The evidence map summarizes patient outcomes reported in reviews of studies in patients practicing Tai Chi for health-related indications. We searched PubMed, DARE, the Cochrane Library of Systematic Reviews, the Campbell Collaboration database, AMED, CINAHL, PsycInfo, Scopus, Web of Science, and PROSPERO; screened reviews of reviews; and consulted with topic experts. We used a bubble plot to graphically display the research field and summarized results narratively in an executive summary.

Tai Chi has been investigated as a treatment for a number of clinical indications. The systematic review identified 107 systematic reviews. Reviews addressing general health effects, psychological wellbeing, or interventions in older adults included between 31 and 51 randomized controlled trials (RCTs). The topic areas balance, hypertension, falls, quality of life, cognitive performance, and vestibulopathy have also been the focus of research; included reviews identified 10 or more pertinent RCTs per topic. Statistically significant effects across existing studies were reported for hypertension, falls outside of institutions, cognitive performance, osteoarthritis, chronic obstructive pulmonary disease, pain, balance confidence, depression, and muscle strength. However, review authors cautioned that firm conclusions cannot be drawn due to methodological limitations in the original studies and/or an insufficient number of research studies.

## BACKGROUND

Many Veterans desire complementary and alternative medicine or integrative medicine modalities, both for treatment and for the promotion of wellness. Given the VA's desire to promote evidence-based practice, this evidence mapping project aims to help provide guidance to VA leadership about the distribution of evidence about Tai Chi to inform policy and clinical decision making.

Tai Chi, also known as T'ai chi ch'uan or Taiijiquan, developed as an ancient Chinese martial art and today is widely practiced for its health benefits. Many forms of Tai Chi exist, but in Western culture, it is most commonly taught as a series of slow, gentle, low-impact movements that integrate the breath, the mind, and physical activity to achieve greater awareness and a sense of inner peace and well-being.1 Tai Chi incorporates the Chinese concepts of yin and yang, which represent two opposing yet complementary forces described in traditional Chinese medicine. The underlying premise is that good health is achieved by balancing these opposing forces. Tai Chi is designed to strengthen and stretch the body, improve the flow of blood and other fluids throughout the body, and improve balance, proprioception and awareness of how the body moves through space. It may be practiced in a group format or alone. Results from the 2007 National Health Interview Survey – a national survey conducted on a representative sample of adults in the US – estimates that approximately 2.3 million adults in the U.S. had practiced Tai Chi in the past 12 months.2 There is no official licensure granted by national or state professional boards, and there are no official standards for training instructors. Rather, students are taught by a master, and then teach with the master's approval. Thus, training programs vary.

## KEY QUESTIONS/SCOPE OF PROJECT

The project deliverables are:

- An Evidence Map that provides a visual overview of the distribution of evidence (both what is known and where there is little or no evidence base) for Tai Chi; and
- A set of executive summaries that would help stakeholders interpret the state of the evidence to inform policy and clinical decision making.