# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comment | Response
The effect on pulmonary function causes me to wonder how tai chi would compare to pulmonary rehab programs and also cardiac rehab programs. | We did not identify a summary estimate of the comparative effectiveness of Tai Chi and pulmonary or cardiac rehabilitation programs
This is a rapidly moving field and although this meta-analysis of existing reviews is very comprehensive there will be always studies published right after the completion of a manuscript that could not be taken into account at the time. However, I think several studies have been recently published on the topic of Tai Chi and Parkinson's disease that would be worthwhile to consider in this context (see below). Tai chi and postural stability in patients with Parkinson's disease. Li F, Harmer P, Fitzgerald K, Eckstrom E, Stock R, Galver J, Maddalozzo G, Batya SS. N Engl J Med. 2012 Feb 9;366(6):511-9. | The RCT is included in the VA priority area section (fall prevention)
A randomized trial of tai chi for fibromyalgia. Wang C, Schmid CH, Rones R, Kalish R, Yinh J, Goldenberg DL, Lee Y, McAlindon T. N Engl J Med. 2010 Aug 19;363(8):743-54. | The RCT is included in the systematic reviews on fibromyalgia58,76
Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. Logghe IH1, Zeeuwe PE, Verhagen AP, Wijnen-Sponselee RM, Willemsen SP, Bierma-Zeinstra SM, van Rossum E, Faber MJ, Koes BW. J Am Geriatr Soc. 2009 Jan;57(1):70-5. | We have included the study in the VA priority area section (pain)
What Do We Really Know About the Safety of Tai Chi?: A Systematic Review of Adverse Event Reports in Randomized Trials. Wayne PM1, Berkowitz DL2, Litrownik DE3, Buring JE4, Yeh GY5. Arch Phys Med Rehabil. 2014 May 27. pii: S0003-9993(14)00392-X. | The review was published after the systematic review searches; we have cited it in the future research section
Impact of Tai Chi Chu'an Practice on Balance and Mobility in Older Adults: An Integrative Review of 20 Years of Research. Hackney ME, Wolf SL. J Geriatr Phys Ther. 2014 Jul-Sep;37(3):127-35. | This review was assessed but did not meet inclusion criteria for systematic reviews
J Am Geriatr Soc. 2007 Apr;55(4):511-7.Augmenting immune responses to varicella zoster virus in older adults: a randomized, controlled trial of Tai Chi. Irwin MR(1), Olmstead R, Oxman MN. | The RCT is included in the VA priority area section (pain) and is also included in the systematic review on infections47
Psychosom Med. 2003 Sep-Oct;65(5):824-30. Effects of a behavioral intervention, Tai Chi Chih, on varicellazoster virus specific immunity and health functioning in older adults. Irwin MR(1), Pike JL, Cole JC, Oxman MN. | The RCT is included in the systematic review on infections47
The meta-analysis clearly illustrates that there is an urgent need in standardization of methods and reporting in RCTs. However, by the same token it would be helpful if the current meta-review would be clearer in this respect, too. Key elements for the evaluation of effectiveness of an intervention like standardized effect sizes and targeted outcomes are often not clearly or systematically described. For example, when an RCT for Tai Chi in aging is mentioned in the text without ever mentioning what part of aging was targeted as an outcome it leaves the reader with more questions than answers. | It was outside the scope of the project to reanalyze reported data using standardized effect sizes suitable for all included meta-analyses. All available summary estimates were reported but the choice of outcome measure was the individual study and review authors. We have added a sentence to the data synthesis section clarifying that the evidence map was based on systematic reviews as reported by the review authors. We have added the mean age of the participants to the trial description.
The logic for the graphical representation of the data in Figure 2 is sound. However, I am concerned that key issues such as effect size, overall trial duration, frequency and duration of intervention are not reflected. | The bubble plot can only display information on the review level and individual study-level variables are likely to be a mixture which would be difficult to display. We have added more detail on interventions and followup to the VA priority area sections
Also, it is unclear how to interpret a fairly strong trend for effectiveness that is based on 2 studies (Asthma) versus an unclear trend for Health based +50 studies. Isn't there an issue with sampling and noise (due to different methods across studies)? | The unclear trend for broad areas such as health may have to do with the range of outcomes and indications; we have made this more explicit in the text
Would it be possible to give studies a weighting according to their methods and design? | The bubble plot can only display limited information. Adding methods and design information would mean to give up on one of the other dimensions displayed (number of systematic reviews for the indication, number of RCTs in the largest RCTs, or the summary measure of effect. In addition, only very few dimensions can be feasibly assessed on this level (the evidence map is based on more than 100 systematic reviews, many topics included more than one review, each review summarized several individual studies). To address this point, we have added information on the type of review to the synthesis section; ie Cochrane reviews are characterized by methodological rigor, and results from these high quality reviews are highlighted throughout the text summary
PTSD: Although I appreciate the scarcity of studies on the subject it is important to distinguish combat-related PTSD from other forms of PTSD frequently seen in the civilian population. | We have added a sentence highlighting the absence of combat-related PTSD evidence
I feel that phrases like “systematic review of systematic reviews with a scoping review” could be stylistically improved. | The description of the methodology is designed to facilitate the identification of the review in electronic databases (it is standard terminology)
On page 3, 21 “Search”: it would be important to mention your date cut-off for the search in the final version. | We have added the missing search date to the section
For implementation the type of Tai Chi, group size, length of intervention and length of trial (including long-term follow up) would be important factors. However, I am afraid that sadly most studies do not provide that level of detail. | Recognizing the importance of the information we have added more information on the interventions to the VA priority area sections (where possible, the information is limited)
It's imperative to analyze both sides of the spectrum when reviewing any event, the scientific and experiential, the Yin & Yang, to be able to asses it objectively. Clinical experiential data collected during my years of engagement with GLA VA need to be included for a more rounded, and accurate assessment. | This project is a summary of the published evidence for the VA Evidence-based Synthesis Program; data on clinical experiences would need to be collected in a different project
On Positive Outcomes: These reports need be considered in addition for what they may infer, i.e. .Depression. Chronic emotional states provoke physiological responses, affecting immune and cardio-respiratory function among others. | We are limited in this evidence map to only those outcomes that were reported in the included systematic reviews. We cannot generalize from one outcome to other outcomes. However, all published pooled results have been reported, including physiological responses, immune and cardio-respiratory function
On Inconclusive Outcomes: These should be included only after verifying the studies have fulfilled the requirements of proper scientific and Tai Chi methodology. | The evidence map provides a broad overview of the existing evidence base. Assessing the study quality of each relevant study requires a systematic review focused on a specific clinical condition and outcome and would be a separate project from this evidence map. The reviewer should propose to the ESP leadership that one of the ESP Centers conduct a systematic review for any or all of the conditions in this unclear evidence category for which the reviewer has concerns, eg, a systematic review of Tai Chi effects on Parkinson's Disease
Outcomes are mainly influenced by the Tai Chi instructional program or method selected and least by the Style. All Tai Chi Styles adhere to the same basic principles. | We have added more information on the intervention program in addition to the Tai Chi style.
Personal Experience: This research summary doesn't accurately reflect, and in many instances, contradicts my findings in more than 30 years of teaching and practice experience. | We acknowledge the comment; however, the evidence map summarizes current research evidence as reported in systematic reviews and cannot incorporate individual personal experiences
This is my first encounter with the bubble plot style evidence map. It gives a very nice, visual overview of the topic. If there is interest in a specific diagnosis, more detail can be obtained by the executive summary. Although a lot of work was put into this project, I question how much this format will actually help with decision making and implementation. The problem is that this is a review of reviews. This method has the effect of diluting and homogenizing the evidence to the point that it is no longer helpful for decision making. The details really are important, and these can only be found in the original studies. This is particularly true for non-standardized therapies like Tai Chi. We need to know what was done and how they did it to get the outcome they report. This can then help guide implementation of a Tai Chi program. Our facility has done this for the diagnosis for fibromyalgia. When we looked at the original literature, there were some good studies that showed a good positive effect. Their methods seemed similar to what we would offer and based on this we added Tai Chi to the treatment protocol for fibromyalgia. To be sure, there were also less positive studies out there but they were using different protocols. This kind of helpful detail is lost in the review of reviews. | This evidence map is primarily designed to provide a broad overview. However, to address this point we have reworded the abstract and added more detail on those studies that reported positive effects in the VA priority areas to provide more information relevant to clinicians
Under inclusion criteria (p.3, lines 5-7, and 7-11), please clarify. Word usage and parenthesis usage make this section hard to understand. | Edited for clarity
P. 13, lines 15-16: How were “Most promising areas” identified as such? | The section summarizes research areas that reported positive effects across individual studies; we have added more detail to the introductory paragraph
I am a clinician and not a researcher so I am not the most knowledgeable when it comes to the statistical manipulation of data. I do serve on committees that make decisions about clinical implementation. This report seems well done but I'm not sure this format helps with decision making. This format may be more useful with standardized therapies such as medications. Non-standardization has long been the Achilles heel in evaluating the evidence for complementary therapies. | The evidence map format was specifically requested to provide an overview over this broad research field We have expanded the limitation section to acknowledge that additional implementation variables are needed to inform policy and clinical decision making