# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

We identified 14 good quality systematic reviews (reported in 16 publications) of risk assessment tools and risk factors, as well as five primary studies of risk assessment tools and 25 primary studies of risk factors. Risk assessment tools and risk factor primary studies were performed in Veteran and military populations. We examined studies from a limited time period (2005 through November 2011) due to the publication of two systematic reviews with similar scope published in 2004 and 2005.^4, 5^

We conducted this report in order to gather the most up-to-date information on suicide prevention, with a particular emphasis on Veterans and members of the military. To do this, we examined systematic reviews conducted since the Gaynes and Mann reports,4, 5 as well as primary articles focused on Veterans and members of the military. In all studies, we considered quality of design and implementation in order to best assess the strength of evidence provided. Though some studies may not be affected by certain design or implementation flaws, many studies related to suicide are complex and difficult to implement in a manner free of risk of bias. For example, studies examining suicide as an outcome may not have a significantly increased risk of bias if outcome assessors are not blinded; this is because suicide is a relatively objective outcome to assess. Suicide behavior and other aspects of suicidal self-directed violence, on the other hand, though they may appear objective, often require subjective decision-making when assessed by methods such as chart review due to variation in documentation and in definition of the outcome. Likewise, when risk factors are assessed by chart review, the same potential for bias exists if assessors are not blinded to the suicide outcome status. These quality considerations were reported with the data obtained from all included studies.

### Systematic Reviews

Though we found 34 systematic reviews conducted since 2005, none of the 14 high quality reviews provided sufficient evidence for suicide risk assessment tools and suicide risk factors due to the variations in the scope of the reviews. We further examined all primary studies cited in these reviews if they met our inclusion criteria, and we included these studies in our synthesis of primary studies, listed by key question below.

#### Key Question #1 What assessment tools are effective for assessing risk of engaging in suicidal self-directed violence in Veteran and military populations?

Evaluation of the effectiveness of risk assessment tools is lacking, both among existing reviews with a more broad focus than this report, and among the studies examined in this report which focus on Veterans and members of the military. The three existing systematic reviews covering this topic all came to similar conclusions, noting the dearth of evidence from prospective studies examining associations among suicide prevention assessment tools and suicidal self-directed violence outcomes. Two non-systematic reviews on the topic came to similar conclusions. The Brown report cites numerous measures that have demonstrated adequate internal reliability and concurrent validity,11 though highlights the Scale for Suicidal Ideation and the Beck Hopelessness Scale as two of only very few measures that have shown associations with death by suicide.

We examined the best available evidence from primary studies related to Veterans and members of the military. Among the five primary studies that met our inclusion criteria, three are of limited quality. There were no studies identified that evaluated whether a risk assessment tool can accurately reclassify Veterans and military personnel from low risk of suicide to higher risk. This leads to an inconclusive rating for the overall strength of evidence regarding assessment tools for suicide. Evidence of accurate reclassification would be necessary to increase this overall assessment of strength of evidence for research investigating suicide risk assessment tools.

Though this relatively small number of studies provides insufficient and low strength evidence for the assessment of suicide risk factors with the tools that were investigated, certain aspects of the findings warrant further discussion. Two of the studies investigated assessment tools commonly used in VA settings: the PAI13 and the BDI-II,14 whereas the other three studies investigated tools not commonly used in VA settings15, 16 or no longer commonly used in VA settings.17 Of these latter three studies of assessment tools less common to VA settings, the IPS is lengthy and the results are seriously called into question due to the method of assessment and group comparison (one group was assessed by estimating history post-mortem and compared to responses from a living comparison group). The study by Hendin et al. investigated the ASQ, a brief screening tool designed to assess risk of suicide.15 Though the sample was relatively small (n=283) and the study was rated as having an unclear risk of bias, preliminarily positive results and ease of implementation suggest that this tool warrants further research investigating potential for use and predictive power in a validation sample of Veterans or members of the military. Finally, the study by Tiet et al. investigating the ASI is useful for gathering information on a large population of Veterans.17 Although this is only one study, the data derive from an entire population of Veterans (34,000) who were administered the ASI, lending support to the strength of evidence for this measure; however, because this lengthy structured interview is no longer routinely used in VA settings, the utility of the ASI as a suicide risk assessment tool is greatly limited.

Of the tools commonly used in the VA, the following describes considerations for implementation as suicide risk assessment tools: the PAI, though commonly used in VAs and other settings as part of lengthy psychological assessments, is difficult to administer without training, time, and electronic scoring software; however, this tool could potentially be used to design new, brief assessment measures based on the content of the subscales and items predictive of suicidal self-directed violence as preliminary evidence from this one study on a small sample of Veterans who had TBIs. Finally, the BDI-II is a brief, easy to administer, easy to score depression screening tool that is commonly used in VA settings. This tool was examined in conjunction with information on participants' previous suicide attempt history. Haiti et al. report promising exploratory model results predicting suicide attempts, though note that in a validation cohort, the model obtained a significantly lower sensitivity score.14 Therefore, though many aspects of the research on the BDI-II are promising, further research is needed to establishing acceptable predictive power before this tool should be considered for widespread adoption. An adapted and shortened version of the PAI subscales and the BDI-II could both potentially be used in primary care settings, though given length and administration considerations, the BDI-II may be more easily implemented in such settings.

#### Key Question #2 In addition to the risk factors included by current assessment tools, what other risk factors predict suicidal self-directed violence in Veteran and military populations?

Studies of risk factors related to suicide indicate that psychiatric conditions are associated with suicide, especially depression and anxiety. Evidence is conflicting about whether PTSD is an independent risk factor in all or just some populations.

We identified 26 studies meeting inclusion criteria that addressed risk factors for suicidal self-directed violence in Veteran and military populations. All evaluated risk factors after accounting for variance associated with other previously established risk factors. Four of these were determined to have unacceptably high risk of bias and, therefore, are not discussed further. The remaining 22 studies were all determined to have unclear risk of bias. No studies had low risk of bias. Limitations in study design and analysis that led to a rating of high or unclear risk of bias included: assessment of suicidal behavior by chart review only, a method that is biased by provider assessment and documentation (or lack of assessment and documentation) about the behavior; lack of assessor blinding when utilizing chart review of assessment of risk factors; use of ICD-9 chart diagnoses for determination of risk (as opposed to a clinician administered tool or history); recruitment methods that reflect a non-representative population; failure to report on the handling of missing data; among others.

### Suicide attempts

Nine studies of suicide attempts used longitudinal, cross-sectional and case-control analyses to assess risk factors (two not discussed further because of high risk of bias). Suicide attempt outcomes were often self-report and occasionally objectively documented (by clinician referral or hospital admission). Factors that were significant predictors of suicide attempts were: prior suicide attempt and depressive symptoms as measured by the BDI,14 suicide or psychiatric symptoms (a composite of variables based on multiple aspects of suicidality from the ASI), alcohol and cocaine abuse.28 Protective factors included: involvement with the criminal justice system and number of days participating in substance abuse treatment program. In a study of Canadian military personnel having purposely injured or killed, toxic chemical exposure, life-threatening illness, and being a civilian in religious terror (being a civilian in a place where there was ongoing terror of civilians for political, ethnic, religious or other reasons) were significant predictors of suicide attempts among men.18, 19 In this study, women differed from men as to which variables predicated suicide attempt; risk factors for women tended to classified as “traumatic.”

### Death by suicide

Risk factors for death by suicide were assessed in 15 studies (two not discussed further because of high risk of bias; Tables 1 and 2). Outcome determination used NDI data linked with other types of registries and hospital records. Risk factors that were associated with death by suicide in more than one study include: white race, bipolar disorder and substance abuse. Several risk factors were only significant (or reported) in one study of death by suicide: education, alcohol abuse, TBI, diabetes, cerebrovascular disease, lower MCS-12 scores reflective of mental health functioning, severe pain and activity limitations. Others had mixed results, with some but not other studies finding significant association with suicide: male gender, age, anxiety, number of psychiatric conditions, PTSD, depression, anxiety, schizophrenia, history of inpatient psychiatric hospitalization, alcohol abuse and non-service connected Veteran status. Admission to a nursing home was found to be protective in one study.

Combining risk factors for suicide attempts and death by suicide may give a more thorough picture of suicide risk factors; however, doing so with the studies reviewed here does not shed substantially greater light. For PTSD, depression and psychiatric conditions, including the data from suicide attempts (in addition to the data from suicides) support these variables as risk factors for suicide. Many other risk factors remain evaluated in only one study.

## LIMITATIONS

The highest quality evidence for risk assessment tools and risk factors derives from studies that evaluate tools or variables in a population and then follow that population for the development of the outcome. New risk factors must account for known risk factors so that conclusions can be drawn about whether the risk factors act independently or through other known mechanisms. Thus, studies of risk instruments have the potential to be limited by their study design (cross-sectional rather than prospective design), method of assessment of risk factors (clinician-generated diagnosis of depression versus a diagnosis of depression based on administrative codes or self-report symptom measure), and the lack of adjustment for confounding variables. For this review, we excluded many articles because they did not adjust for appropriate confounders. Careful attention to collection and adjustment for known confounders will be important for any research going forward.

We limited our search to studies on Veterans and/or members of the military. Though we chose to apply this limitation for reasons of improved generalizability given the unique risk factors experienced by the populations of interest, it is likely that important lessons could be learned from studies utilizing non-Veteran and non-military populations, and findings from such reports (e.g., the Mann, Gaynes, and NICE reports summarized in this current review)4-6 should be considered in spite of their broader focus. Despite this restriction to Veteran and military populations, the included studies in this current report remained sufficiently heterogeneous to preclude meaningful quantitative synthesis and comparison.

Studies varied in terms of population (Veterans with mental health disorders or substance use disorders, including those with recent/current psychiatric admission versus active military), settings and risk factors assessments. Inherent to this type of research is the fact that risk factors differ between populations according to the prevalence of underlying conditions in that population. Thus, in cases where there is discrepancy about whether a certain predictive factor conveys risk, protection or is neutral (as is the case with PTSD), population differences may be part of the explanation.

Some of the factors determined by these studies are specific to the populations studied. For instance, Ilgen et al. found that number of treatment days was an important protective factor in their study of suicide after admission to inpatient substance use disorders program.28 Clearly, this protective factor is not generalizable to populations of Veterans that have not been admitted to an inpatient treatment unit. There may be other risk factors that differ substantively between populations for other less readily apparent reasons.

Another potential limitation of this literature is the use of suicide attempts as an outcome. This outcome has high potential for misclassification bias. That is, assessment of suicide attempts relies on accurate assessment and documentation by the provider as well as accurate reporting by the patient. There is potential for under- and over-reporting in both instances. For this reason, documented suicide attempts that result in hospitalization or ER visits are more rigorous outcomes than self-reported suicide attempts.

Overall, the literature demonstrates a large group of associated risk factors that have been evaluated in various heterogeneous populations within Veteran and military groups. There have been few studies of active military personnel and women. These factors limit our ability to draw strong conclusions about risk factors that predict suicide for the entire Veteran and military population.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Research on suicide is inherently difficult because of the very low base rate occurrence of both suicide and suicidal self-directed violence in general populations. Therefore, future studies of both risk factors and risk assessment tools should utilize adequate sample sizes to achieve sufficient power to detect changes in rates of suicide and suicidal self-directed violence.

Future research needs to focus on critical evidence gaps. There is a striking lack of assessment tool evaluation research among Veteran and military populations. Several risk instruments have been developed and tested in other populations: the Suicide Assessment Checklist, the Manchester Self-Harm Rule, the Suicide Probability Scale, the Suicide Ideation Questionnaire, the Suicide Risk Assessment Scale, and the Beck Scale for Suicide Ideation, among others.110-117 A reasonable next step would be to test some of these instruments in Veteran and military populations. Research would ideally be prospective and involve adequately blinded assessment techniques to reduce potential bias. Moving forward, it will also be important for studies of risk assessment tools to evaluate how well these tools discriminate people who will go on to attempt or die by suicide from those who do not.

VA medical centers and the military already use assessment tools to screen for mental health disorders associated with suicide (e.g., depression, substance use disorders, and PTSD), as well as measures designed to screen for suicidal ideation and intent. These screening tools are implemented among large, general populations of Veterans and members of the military, and are often scored and recorded in EMRs. We did not find any articles examining whether or not these measures predicted suicidal self-directed violence, though some information was available related to the Patient Health Questionnaire-9 (PHQ-9), a measure developed to screen for depression and currently broadly implemented in VA settings. One item on the PHQ-9 is designed to assess suicidality, though studies have validated this item for suicidal ideation only, as reported in follow-up clinical interviews, not suicide.118, 119 Though this PHQ-9 item has been associated with suicidal ideation, controversy remains about whether it is an appropriate assessment tool for suicide. Critics note the vague and multi-component nature of the PHQ-9 suicidality item,120 while proponents counter that the suicidality item should necessarily prompt further questioning that would lead to additional (adequate) assessment of suicidal ideation and plans.120 Future research should investigate the predictive power of both the PHQ-9 and other commonly used tools implemented in VA and military primary care settings. If any such assessment tools are predictive of suicidal self-directed violence, researchers should establish cutoff scores to classify suicide risk.

Another notable gap in the literature is related to the relative paucity of research conducted with members of the military compared to studies focusing on Veterans. One reason that there are several studies using VA data is because the VA has a comprehensive clinical data source that is available for linkage with other national databases (NDI, etc.). If similar data were available for the active military population (perhaps from the military suicide event reporting database, DODSER) and/or the full complement of Veterans and military, then this could enable strong research to be completed in the military population.

An interesting question is that of coordination of care transitions and the role that the system (military, VAMC or hospital, primary care provider) plays in helping to prevent suicide. Desai et al. suggest that improved access to care in the first six months after psychiatric hospitalization is beneficial for preventing suicide attempts.24 Therefore, researchers might think broadly about settings in which suicide risk assessment tools are applied, such as during or immediately following inpatient hospitalization. Studies to test risk assessment tools that predict suicide attempts across multiple settings such as primary care physician visits, post-discharge (through a post-discharge follow-up phone call or visit), etc. could be valuable.

Future studies about risk factors need to address and account for known risk factors carefully. Future research should focus on determining factors that provide additional predictive power above and beyond known risk factors such as previous suicide attempt history, depression and other mental health diagnoses, and substance use disorders. Ideally, this research would be prospective, involve adequately blinded assessment techniques to reduce potential bias, and utilize adequate sample sizes to achieve sufficient power given the very low base rate occurrence of both suicide and suicidal self-directed violence. Given the unique risk factors often faced by Veterans and members of the military (e.g., combat-related PTSD, TBI, etc.), these emerging risk factors should be a particular emphasis of future research. Research in this area may also move towards an examination of warning signs, factors that are thought to signify more immediate state of risk, as opposed traditional risk factors that reflect an overall heightened state of risk. Identification of short-term warning signs could identify certain populations who need more immediate intervention.

Future research is necessary to better understand differences in risk factors among populations. In particular, the differences between risk factors for suicide among men and women are understudied. Despite the fact that the majority of suicides in the Veteran population occur in men, women have different risk factors predictive of suicide and could need different interventions in order to reduce suicide rates.

## CONCLUSIONS

KQ# | Key Question | Type of Evidence | Quality of Evidence | Comments
1 | What assessment tools are effective for assessing risk of engaging in suicidal self-directed violence in Veteran and military populations? | 5 studies testing validated measures in Veteran or military populations | 2 studies had unclear risk of bias; 3 studies had high risk of bias | Insufficient evidence overall to recommend screening with these risk assessment tools based on this evidence. Future research is warranted, particularly for risk assessment instruments that are already in use within the VA system.
2 | In addition to the risk factors included by current assessment tools, what other risk factors predict suicidal self-directed violence in Veteran and military populations? | 25 studies of risk factors for suicide attempts and suicides among Veteran and military populations | 21 studies with unclear risk of bias and 4 studies with high risk of bias | Insufficient evidence overall. Strongest evidence exists for risk factors that have been previously identified (white race, male gender, psychiatric disorders, substance use disorders, and trauma). More research is warranted to understand emerging risk factors in younger Veteran and military populations.