# RESULTS

## LITERATURE FLOW

We reviewed 16,426 titles and abstracts from the electronic search, and an additional 95 from reference mining for a total of 16,521 references. After applying inclusion/exclusion criteria at the abstract level, 15,743 references were excluded. We retrieved 778 full-text articles for further review and another 732 references were excluded. We identified a total of 46 references for inclusion in the current review, including 30 observational studies and 14 systematic reviews (reported in 16 publications). We grouped the studies by key question and study design. Figure 2 details the number of references related to exclusion criteria and publication type.

Figure 2 Literature Flow Chart^a^

^a^ Modified from the PRISMA flow diagram.70

^b^ 1,336 primary risk articles in a non-Veteran or military population were excluded after reviewing the publication's abstract; 123 were excluded after reviewing the full publication.

## SYSTEMATIC REVIEWS

We identified 34 systematic reviews (reported in 38 publications) of risk assessment tools and risk factors associated with suicidal self-directed violence.71-108 Using the Oxman and Guyatt criteria, we assessed these reviews for risk of bias (Appendix F).8 Fourteen reviews had minimal flaws (a rating of 6 or 7); these are summarized in Appendix G.74, 76, 79, 83, 86, 88, 89, 91, 94-97, 104,105, 107, 108 The usefulness of these reviews to this report is limited, however; 6 of 14 reviews did not include any studies meeting our eligibility criteria, and no review focused on Veteran or military populations.

## KEY QUESTION #1 What assessment tools are effective for assessing risk of engaging in suicidal self-directed violence in Veteran and military populations?

### Summary of prior reviews on risk assessment tools in non-Veteran and non-military populations

In order to provide background on the literature prior to 2005 and in civilian populations, we highlight findings from several existing reviews on suicide assessment tools in any population. These reports include systematic reviews of suicide by Mann et al., Gaynes et al., and one on repetition of self-harm by NICE in 2011;^4-6^ as well as two non-systematic literature reviews that provide comprehensive lists of over 60 existing suicide assessment tools for adults and older adults by Brown, and for children and adolescents by Goldston.11, 12

Brown and Goldston11, 12 are non-systematic reviews that describe the psychometric properties and validation studies for measures designed to assess suicidal ideation and behavior. The Brown report cites numerous measures that have demonstrated adequate internal reliability and concurrent validity, though it highlights the Scale for Suicidal Ideation and the Beck Hopelessness Scale as two of only very few measures that have shown associations with death by suicide. The Goldston paper reports that many promising measures for use in child and adolescent populations have insufficient psychometric data, and are in need of further research. Goldston specifically highlights the need for prospective studies examining the association between these assessment tools and death by suicide. Due to the non-systematic nature of the Brown and Goldston papers,11, 12 and the fact that their specific inclusion criteria were different from the criteria used for our current review, findings should be interpreted as such, and not combined in an additive manner with findings from this report. However, researchers and providers seeking information on existing assessment tools will find these reports to be a resource for descriptive and validity information on such tools.

The three systematic reviews, Mann et al., Gaynes et al. and NICE 2011,^4-6^ each highlight the need for further prospective research to establish the effectiveness of these assessment tools in predicting suicidal self-directed violence. The authors all note that current research is insufficient to determine definitively whether or not there is a benefit in implementing existing screening tools for the prevention of suicide. The NICE 2011 review is the most recent and comprehensive review of suicide risk assessment tools. It describes findings from six cohort studies that examine tools for prediction of death by suicide among people with prior non-fatal self-harm. The authors conclude that several limitations of the whole body of literature preclude recommendation of these suicide risk assessment tools for use in clinical practice: short follow-up periods of the studies, inadequate sample sizes needed to detect effects on low base-rate outcome, and overall high rates of false positive identification of individuals as being at risk for suicide. This report also investigated scales designed to predict self-harm and described similar limitations among these scales. Specifically, they note that low positive predictive values for these scales indicate that individuals are likely to be over-identified as being at risk, which has the potential to result in unnecessary intervention for some individuals. Overall, the findings from the Mann, Gaynes, and NICE reviews concur in their reports of limited evidence available on the effectiveness of suicide risk assessment measures in prevention of suicidal self-directed violence. We summarize assessment results from these reports in Appendix H, describing the scope as well as the findings.

### Primary studies of risk assessment tools in Veteran and military populations

Given the limited evidence available on effective suicide risk assessment tools, we examined the best available evidence specifically related to Veteran and military populations. We included five articles13-17 that met our inclusions criteria and described assessment tools used within military or Veteran populations (Appendix I), three of which had methodological flaws resulting in a high risk of bias,13, 14, 16 and two of which were rated as having unclear risk of bias (Appendix J).15, 17

Hendin et al. examined a brief screening tool, the Affective States Questionnaire (ASQ), as a predictor of suicidal behavior.15 This study was conducted among a population of 283 Veterans receiving inpatient or outpatient services at a Veterans Affairs Medical Center (VAMC). The ASQ increased odds of prediction of future suicidal behavior by 2.4 in a logistic regression model adjusting for sex, substance abuse, and severity of depression. Using a cutoff of ≥3, the ASQ resulted in sensitivity of 0.60 and specificity of 0.74 in this population. The authors report preliminary validity information for the ASQ, and the study obtained a rating of unclear risk of bias because of insufficient information on how patients were selected to participate and no information on assessor blinding when assessing the suicidal behavior outcome. Because of the unclear risk of bias and relatively small sample size, this one study provides insufficient evidence that the ASQ predicts suicidal behavior. However, because of the initially promising results even after adjusting for known risk factors, as well as the potential utility of such a brief screening tool in primary care settings, future research on the predictive power of the ASQ is warranted.

Tiet et al. investigated the use of the Addiction Severity Index (ASI), a lengthy structured clinical interview designed to be used as an intake interview for a substance abuse treatment program.17 Their study examined over 34,000 Veterans who were assessed for intake as part of substance abuse treatment at 150 VAMCs nationwide. This assessment tool is not ideal for settings that require brief screening tools, though VAs used to use this assessment routinely, and, therefore, the information is readily available in a large number of Veteran medical charts for those Veterans who received substance abuse treatment in the past. As such, the information provided in this article is helpful in establishing risk factors based on an entire population of Veteran responses to routine intake items within the timeframe covered in the study. The authors report a decision tree, delineating all significant risk factors to predict future suicidal behavior. The significant predictors were suicide attempt history, suicide ideation history, recent alcohol abuse, recent cocaine abuse, violent behavior, hallucinations, and employment status. This article was rated as having an unclear risk of bias, largely because of the unclear independence of assessors; however, because of the large sample size (i.e., the entire population of Veterans who completed a structured and electronically documented substance abuse intake process), this single study provides moderate strength of evidence for the reported risk assessment capabilities of the ASI. As noted, however, the ASI is no longer routinely used in VA settings.

Breshears et al. investigated the use of the Personality Assessment Inventory (PAI) in a population of 154 Veterans with a history of TBI.13 The PAI is a lengthy assessment tool designed to be administered by a psychologist in the context of an in-depth psychological assessment. Two PAI subscales are designed to assess aspects of suicidality, and these two subscales were investigated as predictors of future suicidal behavior as documented in patient's charts. Breshears evaluated one of the subscales of the PAI, the Suicide Potential Index (SPI), and found that it predicted suicidal behavior after controlling for other risk factors. Although this measure is frequently used in VA settings as part of psychological assessments, it is not well suited for use as a brief screening tool and, therefore, would be less useful in primary care settings. The lack of applicability to primary care settings is related to the lengthiness of the overall measure, the computer scoring methods, and the training/educational requirements required for interpretation and scoring. The various subscale items are embedded within the overall assessment tool, making partial administration of specific subscales difficult if not impossible. The results suggest potential additive predictive power of the SPI subscale. However, the high risk of bias rating of this study due to lack of assessor blinding and other methodological flaws does not allow for strong conclusions on the basis of this study. Although lack of assessor blinding may be less concerning with more objective outcomes such as suicide, this study used chart review to document suicide attempts, making lack of blinding a potential source of bias. More research to confirm these preliminary findings regarding the use of the SPI subscale would be necessary before recommending its use in a clinical setting.

Nademin et al. describe the Interpersonal Psychological Survey (IPS), a 34-item measure, which they report as being associated with increased odds of suicide (Odds Ratio [OR]: 1.27).16 This study, however, was rated as having a high risk of bias due in large part to the inability to account for confounders and differences in assessment techniques between groups. The two groups they examined were 60 members of the Air Force who died by suicide and a matched sample of 122 members of the Air Force. Due to the retrospective nature of the study investigating suicide as the primary outcome, assessors estimated scores on the assessment tools for the groups of participants who died by suicide, whereas the control group participants completed the measures by self-report. This difference in assessment techniques and other confounders associated with the groups being compared results is insufficient evidence that the IPS predicts suicide.

Hartl et al. reported findings for a sample of 630 male Veterans diagnosed with PTSD and participating in a residential treatment program.14 They examined the Beck Depression Inventory-II (BDI), a 21-item, commonly used depression screening tool which includes an item asking about suicidal ideation. This measure, due to its brevity, frequent usage, and ability to be administered, scored, and interpreted by a variety of providers, has potential for widespread implementation in VA and military settings. Though the authors found that previous suicide attempt (four months prior to intake) was the strongest predictor of future suicide attempt following discharge, they report that BDI-II score was also a significant predictor of future suicide attempt. They reported model sensitivity of 0.63 and specificity of 0.80 in their exploratory sample of 409 Veterans. The replication study examining data on the remaining 221 Veterans used the cutoffs established in the exploratory study. Contrary to the exploratory model, the replication model resulted in sensitivity of 0.11 and specificity of 0.84. Overall, this study provides insufficient evidence for the BDI-II in predicting future suicide attempts in a Veteran population with PTSD due to the inconsistent results as well as the high risk of bias rating of this study.

## KEY QUESTION #2 In addition to the risk factors included by current assessment tools, what other risk factors predict suicidal self-directed violence in Veteran and military populations?

### Summary of prior reviews on risk factors for suicide in non-Veteran and non-military populations

Though existing systematic reviews on this topic were outside the scope of this report due to their focus on civilian populations, in order to provide a comprehensive report on risk factors for suicide, we highlight findings from existing systematic reviews of risk factors in any population. These include systematic reviews on suicide by Mann et al., Gaynes et al., and on repetition of self-harm by NICE in 2011.^4-6^ Mann and Gaynes did not address literature assessing the strength of individual risk factors, but the NICE report did perform a comprehensive review and meta-analysis of risk factors. The NICE report methodology differs from that used for this report in several ways: 1) they included only prospective studies evaluating risk for repetition of self-harm; 2) they included studies from other countries outside the scope of this report; and 3) they included studies that were minimally adjusted for confounders (other risk factors that might explain the association - e.g., mental health diagnoses; some studies did not assess or adjust for mental health diagnoses in evaluating other risk factors for suicide).

The NICE report found that the following factors predicted non-fatal repetition of self-harm in adults:6 prior self-harm and depression symptoms, schizophrenia and related symptoms, alcohol misuse, other psychiatric history, unemployment and “registered sick”, female gender (mixed and poor quality evidence), unmarried status (narrative evidence only; not predictive in pooled analysis), and younger age. The following symptoms predicted suicide among adults with prior self-harm: suicide intent/intent to die, male gender, psychiatric history, older age, violent methods of self-harm, physical health problems (mixed evidence), and alcohol abuse (mixed evidence). Risk factors for repeated self-harm among young people were similar to those identified for adults. Given these differences between our report and the NICE review, these findings should be interpreted with some caution.6

### Primary studies on risk factors for suicide in Veteran and military populations

We identified 26 studies that evaluated risk factors to predict suicide behavior outcomes (Appendix K).14, 18-42 Table 1 in this section lists all risk factors identified and the studies that contributed to evidence for that risk factor. Table 2 lists all studies with information on study design, population, outcome and risk of bias for each included study.

Studies of risk factors for suicide were longitudinal, cross-sectional and case-control in their design. Many utilized existing VA databases linked with clinical (inpatient or outpatient), administrative, or large survey databases either alone or linked with another data sources. The populations represented in these studies are US Veterans in 18 studies, active duty US military personnel in four studies and other military populations in four studies. Outcomes include death by suicide in 15 studies, self-reported suicide attempts in 11 studies, and objective suicidal behavior assessed by chart review or clinician referral, or admission for suicide attempt in two studies.

Risk of bias for the 26 identified studies is included in Appendix L. Four studies had a high risk of bias and, therefore, are not discussed further in this report.33, 34, 39, 40 The remaining 22 studies were rated as having unclear risk of bias. No studies had low risk of bias, a determination that requires that a study satisfy all quality criteria. Limitations of the studies evaluated here that accounted for high or unclear risk of bias include: assessment of suicidal behavior by chart review only, a method that is biased by whether the provider chooses to document suicidal behavior; use of ICD-9 codes for risk factor assessment; assessment of suicide attempts by self-report; failure to report specific details of recruitment process (how many screened, how many agreed to participate and actually provided data); failure to report on the handling of missing data; and recruitment of potentially biased study population (as in patient sample with non-random treatment assignment when medication is the risk factor). As explained in the Methods section, we excluded studies that had inadequate control for potential confounding variables and randomized controlled trials that did not account for treatment group. The remaining studies are reported below.

#### Studies that assess risk factors for self-reported suicide attempts

##### Longitudinal designs

Two studies that utilized a self-reported suicide attempt outcome were longitudinal.14, 28 Hartl et al. enrolled male Veterans who were entering a residential treatment program for PTSD. Predictive variables were obtained at enrollment in the program and suicide attempts were assessed four months following discharge from the program. Having attempted suicide in the four months prior to enrollment was the best predictor of suicide attempt following discharge. Among those who had not attempted suicide in the four months before enrollment, suicide attempts following discharge were predicted by depressive symptoms (based on scores on the BDI).14 No data are provided about how various levels of BDI scores predict suicide attempts.

Ilgen et al. reported on how the ASI109 administered within two weeks of entry into a VA addiction treatment program predicted suicide one year later.28 Factors that predicted suicide attempts were: elevated suicidal/psychiatric symptoms based on the ASI, alcohol problems, and cocaine-adjusted life years; protective factors were: involvement with the criminal justice system and the number of days of participation in substance use disorder treatment.28 For this study, the authors used factor analysis to create the variable, “suicidal/psychiatric symptoms,” by combining four other positively correlated and overlapping variables: number of psychiatric problems in the 30 days prior to baseline, number of previous inpatient psychiatric treatment episodes, whether the patient reported being on psychiatric medications at baseline, and a variable for lifetime suicidality that was derived from lifetime suicidal ideation and lifetime suicide attempts.

##### Cross-sectional designs

Five studies assessed self-reported suicide attempts using a cross-sectional study design and were rated as having unclear risk of bias.18, 19, 36, 37-42 Two of these used active duty military Canadian military personnel.18, 19 Evaluating specific types of trauma, Belik et al. 2009 found that suicide attempts among men were associated with having purposely injured or killed, toxic chemical exposure, and life-threatening illness; and being a civilian in religious terror. Suicide attempts among women were associated with witnessing a man-made disaster, being a victim of child abuse or other abuse, witnessing domestic violence or being stalked.18 In the second study, Belik at al. 2010 found that depressive episodes, social phobia, alcohol dependence, generalized anxiety disorder and PTSD were associated with increased odds of suicide attempt.19

Tiet et al. examined data from over 33,269 men seeking treatment for substance use disorders, psychiatric disorders or both from the VA healthcare system.37 In multivariate logistic regression models of men, suicide attempt within the past 30 days was significantly associated with sexual abuse (OR 2.08) and physical abuse (OR 2.38) in the past 30 days, lifetime sexual abuse (OR 1.33) before the past 30 days, psychotic disorder (OR 1.48), depressive disorder (OR 2.38), PTSD (OR 1.37), other anxiety disorder (OR 1.45), and personality disorder (OR 1.74). Alcohol abuse or dependence, drug abuse or dependence, marital status, age, and lifetime physical abuse prior to the past 30 days were not significantly associated with suicide attempts.37

Thomsen et al. surveyed 2,116 active duty military personnel in the US Marine Corps and US Navy serving in the US, half of whom had been combat deployed, and questioned them about their behaviors: 1) as a civilian, 2) prior to combat deployment, and 3) subsequent to combat deployment.36 Those who reported a prior suicide attempt had significantly higher odds of a subsequent suicide attempt (adjusted OR 8.58). Marital status (being divorced, separated or widowed) was the only other significantly associated potential risk factor (OR 3.90). This model included gender, age, rank, education, and combat deployment but no variable to account for psychiatric illness.36

Pettit et al. evaluated 298 men and women enrolling in an intervention trial for suicidality recruited from clinics, inpatient wards and the emergency room of a major US Army Medical Center.42 This cross-sectional analysis was designed to evaluate the interaction between negative life events and very early onset psychiatric illness (bipolar disorder, anxiety and major depressive disorder [MDD]). Negative life events were associated with self-reported suicide attempts in those with very early onset anxiety, very early onset MDD, and those without any history of very early onset psychiatric disorder. The interaction term for negative life events and very early onset bipolar disorder was significant, suggesting that very early onset bipolar disorder accounts for the association between negative life events and self-reported suicide attempts in this group.42

#### Studies that assess risk for objectively measured suicide attempts

Two studies have assessed suicide attempts using an objectively measured outcome rather than self-report, both using retrospective study designs.

##### Retrospective Designs

Brenner et al. performed a case control study using Veterans with a history of suicide identified from electronic medical records (EMR) of a VA mental health clinic and age/gender matched controls.21 Having chart diagnoses of both PTSD and TBI increased the odds of suicide compared with those who had TBI only (OR 3.29), and increased the odds compared to having neither PTSD nor TBI (OR=2.54). In models accounting for both PTSD and TBI, PTSD was independently associated with suicide but TBI was not.21 Thus, PTSD appears to be independently associated with suicide attempts, and also appears to increase the odds of a suicide attempt among patients with TBI.

Using a retrospective chart review of randomly selected medical charts from those admitted to a US Army hospital with suicidal behaviors (n=191), Cox et al. evaluated predictors of suicide behaviors.23 Admission for suicidal behavior (as opposed to suicidal ideation) was associated with three types of childhood trauma (sexual abuse, domestic violence and other trauma). When this model was further adjusted for “other trauma,” those associations were no longer significant and indeed this model resulted in no significant risk factors.23 This study was assessed to have unclear risk of bias because all risk factors including trauma were evaluated with chart review.

#### Studies that assess risk factors for suicide

Thirteen studies evaluated risk factors for suicide. Many of these confirmed the suicide by using the National Death Index (NDI) to identify the person and cause of death; others used military records and International Classification of Diseases, Tenth Revision (ICD) chart diagnoses.

##### Longitudinal studies

Eleven studies with death by suicide as the outcome used a longitudinal analysis to assess the contribution of risk factors.22, 24-27, 29, 30, 32, 35, 38, 41 Longitudinal analysis implies that the risk factor was known to occur prior to the outcome. In the case of a suicide death outcome, this will nearly always be the case, independent of whether the potential risk factors were assessed retrospectively (from charts after the time of the suicide) or prospectively (at baseline, prior to suicide). Prospective data collection contributes to lower risk of bias overall.

The studies in this group evaluated the following potential risk factors: PTSD, TBI, psychiatric diagnoses, severe pain, and two health services measures: quality of care measures from recent psychiatric admissions and timing of follow-up following discharge after psychiatric admission.

The studies with longitudinal analysis are reviewed in this section, grouped by their primary variable of interest. In most/all cases, other variables were also included and assessed.

Psychological factors. Several studies by Ilgen et al. evaluate psychological factors using distinct populations and methods. One of these studies utilized data from 3,291,891 Veterans who used VA services in fiscal year (FY) 1999 and were alive at the start of FY 2000 to evaluate associations between psychiatric diagnoses and risk of suicide over the next six years. They found that both male and female Veterans diagnosed with any psychiatric condition were more likely to die by suicide than their counterparts who had no psychiatric diagnoses (Hazard Ratio [HR] for males: 2.50; 95% Confidence Interval [CI], 2.38 to 2.64; HR for females 5.18; 95% CI, 4.08 to 6.58). Indeed, the risk of suicide was increased for those with alcohol abuse or dependence, drug abuse or dependence, bipolar disorder, depression, other anxiety, PTSD and schizophrenia (age adjusted models, HR higher for females than males in every instance). Ilgen et al. did not evaluate all psychiatric diagnoses together in a multivariate model.25 This study was determined to have unclear risk of bias based on lack of reporting of missing data and assessment of risk factors by use of ICD-9 codes.

Ilgen et al. evaluated Veterans with substance use disorders for predictors of violent compared with non-violent suicide compared to controls without suicide over four years (854 suicides and 4,228 controls). Major depression, other anxiety disorders, bipolar disorder, PTSD, schizophrenia, personality disorders and the presence of more than one mental disorder were predictive of both violent and non-violent suicide. Alcohol, cocaine, opiate, and multiple substance use disorders were associated with a higher risk of non-violent suicides compared to violent suicides. None of the factors evaluated were significant for prediction of violent suicide compared to non-violent among those who died by suicide.26 This study was determined to have an unclear risk of bias based on lack of reporting of missing data and assessment of risk factors by the use of ICD-9 codes.

In a separate analysis, Ilgen et al. evaluated 887,859 patients from the VA's National Registry for Depression (NARDEP) for suicide risk factors, specifically race and substance abuse. Risk factors were evaluated between April 1999 and September 2004, and the suicide could have occurred at any time during the study period or in the one year following the study period (total follow-up time of up to 6.5 years, n=1892 suicides). African Americans were significantly less likely to die by suicide than individuals of any other race/ethnicity group. In African Americans with substance use disorder, no other variables were significantly associated with death from suicide. In non-African Americans (primarily white race), death from suicide was associated with having been admitted to an inpatient psychiatric ward in the 12 months prior to the suicide. In those without a substance use disorder, males had almost four times the rates of suicide compared to women.27 This study used a replication cohort to validate their findings. All factors identified in the derivation cohort also significantly discriminated suicides from non-suicides in the validation/replication cohort.

Pfeiffer et al. used the same population of 887,859 Veterans with depression to evaluate other psychiatric diagnoses as potential risk factors for suicide. This study found that the odds of suicide were higher among patients with generalized anxiety disorder and anxiety disorder not otherwise specified, and those receiving anti-anxiety medication.32 Interestingly, PTSD was a predictive factor in this population and several other psychiatric diagnoses were not significantly associated with depression (social phobia, obsessive-compulsive disorder [OCD], all other anxiety disorders).

Zivin et al. used data from 807,694 Veterans (NARDEP data linked with VA Medicare data and NDI; 1,683 suicides over a 5.5 year period) and Cox proportional hazards regression to evaluate PTSD as a risk factor. Among depressed Veterans, PTSD was inversely associated with suicide in the older but not younger depressed Veterans (interaction term PTSD × age ≥ 65 years HR 0.66; 95% CI, 0.44 to 0.99 versus [vs] PTSD × age 45-64 years HR 0.80; 95% CI, 0.58 to 1.01). Other significant predictors of suicide were white race, male gender, non-Hispanic ethnicity, history of substance abuse, younger age (18-44 years), non-service connectedness, and having a history of an inpatient stay for any psychiatric disorder in the previous 12 months.41 This study was rated unclear risk of bias because of lack of information regarding missing data, and lack of reporting about coding process and blinding of raters.

Brenner et al. evaluated data from 7,850,472 Veterans being evaluated in the mental health system (49,626 suicides) with Cox proportional hazards regression models for time to suicide adjusted for psychiatric comorbidities. In this population, 49,626 Veterans had traumatic brain injury (TBI), and 105 had TBI and suicide. To be eligible, Veterans had to have received care between FY 2001 and 2006. Inpatient and outpatient notes were searched for a diagnosis of TBI. Data were linked to the NDI. They found that Veterans with any TBI were 1.55 more likely to die of suicide (HR 1.55; 95% CI, 1.24 to 1.92) compared to those without, after adjustment for age, gender, eight psychiatric diagnoses including substance use disorder, and Veteran Integrated Service Network. Patients with concussion or fracture were 1.98 times more likely to die of suicide; those with cerebral contusion or traumatic intracranial hemorrhage were 1.24 more likely.22 This study was rated as having unclear risk of bias because of lack of information regarding missing data, lack of reporting about coding process and blinding of raters.

Kaplan et al. assessed Veteran status and psychiatric diagnoses using data from US Veterans from the National Health Interview Survey data between 1986-94, linked ot the Multiple Casuse of Death file throug the NDI (1986-97, n=320,890 men followed for up to 12 years). This study demonstrated that Veterans in the US had increased risk of suicide regardless of whether they were associated with the VA. Risk factors for suicide risk among Veterans identified in this study include: white race (compared with non-white race), education level of >12 years (compared with <12 years), and having activity limitations. Interestingly, the number of chronic psychiatric conditions was not a significant predictor for this population (adjusted HR 0.41; 95% CI, 0.14 to 1.26).30 This study was rated as having unclear risk of bias because of lack of information regarding missing data.

Other medical diagnoses. Severe pain: Using data on 5,082 pateints (n=854 suicides and 4,228 who did not die by suicide) from the 1999 Large Health Survey of Veterans (LHSV), VA EMRs and NDI. Ilgen et al. found that severe pain compared to moderate or less pain was associated with higher risk of death by suicide (HR 1.33; 95% CI, 1.15 to 1.54). Other predictors from multivariate models including pain were male gender, white race, smoker status, schizophrenia, bipolar disorder I or II, depression, other anxiety, diabetes, cerebrovascular disease and lower mental health functioning as measured by the Mental Component Summary (MCS).29

Seyfried et al. evaluated 294,952 (n=241 suicides) VA patients over age 60 with dementia drawn from national data.35 Variables associated with suicide included: white race (OR), depression but not other psychiatric diagnoses (OR 2.0, 95% CI, 1.5 to 2.9), history of inpatient psychiatric hospitalizations (OR 2.3, 95% CI, 1.5 to 3.5), and having filled prescriptions for either antidepressants or anxiolytics (OR 2.1, 95% CI, 1.6 to 2.8 for antidepressants; OR 2.0, 95% CI, 1.5 to 2.7 for anxiolytics). In this population, admission to a nursing home was protective (OR 0.3, 95% CI, 0.1 to 0.8).

Health services factors. Hospital quality factors: Desai et al. evaluated suicide risk using data from 128 psychiatric inpatient units within US VA hospitals. They adjusted multivariate models for psychiatric diagnosis, age, race, gender, discharge to the community, distance to nearest VA medical center and year of discharge. Higher risk of suicide was predicted by shorter length of stay (<14 days, RR 1.41, p<0.04), time to readmission (>180 days, RR 0.55, p=0.0001 and poor continuity of care following discharge (1 reference vs none, RR 1.59, p<0.03). Readmission within the six months following hospitalization was protective.24

Timing after treatment interventions: Valenstein et al. evaluated 887,859 Veterans with depression (NARDEP merged with NDI data) and found that suicide events were highest in the first 12 weeks following psychiatric hospitalizations compared to the second 12 weeks (RR 1.9; 95% CI, 1.5 to 2.4), and higher in the 12 weeks following changes in antidepressant regimen (new antidepressant starts, adding another antidepressant, and dose changes) compared to the second 12 weeks (RR 1.8; 95% CI, 1.5 to 2.1).38

##### Retrospective case-control studies

In US Army soldiers, the adjusted odds for suicide were higher among those with a preceding hospitalization for alcohol, injury or mental disorder. Age and male gender were also associated with increased odds of suicide. Protective factors include: time in service (years), black race, less than college education, being married, and ranks as a warrant officer or commissioned officer.20

Among Irish Defense Forces personnel, firearm suicide was associated with psychiatric illness or a history of deliberate self-harm, performing morning duty, and a recent medical downgrading.31

## SUMMARY OF FINDINGS

Table 1 Summary of risk factors and associations with suicide attempts and suicides

| Evidence for Suicide Attempt | Evidence for Suicide
Demographic factors
Male gender | | (+) llgen 2009^27^ (+) llgen 2010^29^ (+) Zivin 2007^41^ (NS) Seyfried 2011^35^
Age | (-) Tiet 2006^37^ (older age protective) | (+) Zivin 2007 (18-44 years)41 (NS) Seyfried 2011^35^
White race | | (+) llgen 2009 (African American race protective)27 (+) llgen 2010^29^ (+) Kaplan 2007^30^ (+) Zivin 2007^41^ (+) Seyfried 2011^35^
Marital status | (+) Thomsen 2011^36^ (NS) Tiet 2006^37^ | (NS) Seyfried 2011^35^
Education | (NS) Thomsen 2011^36^ | (+) Kaplan 2007^30^
Smoking | | (+) Ilgen 2010^29^
Psychiatric factors
Psychiatric Conditions | (+) Ilgen 2007 (composite variable)28 (+) Tiet 2006 (psychotic disorder, personality disorder)37 (+) Ilgen 2010 (men and women)25 | (+) Ilgen 2010 (personality disorder and presence of more than 1 psychiatric diagnosis)26 (NS) Kaplan 2007 (number of chronic psychiatric conditions)30
PTSD | (+) Belik 2010^19^ (+) Brenner 2011^21^ (+) Ilgen 2010 (men and women)25 | (+) llgen 2010^26^ (-) PTSD was protective in Zivin 2007^41^ (-) PTSD was protective in Pfeiffer 2009^32^ (NS) Seyfried 2011^35^
Depression | (+) Hartl 2005^14^ (+) Belik 2010^19^ (+) Tiet 2006^37^ (+) llgen 2010^25^ | (+) llgen 2010^26^ (+) llgen 2010^29^ (NS) Pfeiffer 2009^32^ (+) Seyfried 2011^35^
Bipolar Disorder | (+) Ilgen 2010 (men and women)25 (+) Pettit 2006 (very early onset bipolar disorder)42 | (+) llgen 2010^26^ (+) llgen 2010^29^
Anxiety | (+) Tiet 2006^37^ | (+) llgen 2010(men and women)25 (+) llgen 2010^26^ (+) llgen 2010^29^ (+/NS) Pfeiffer 2009 (some but not all anxiety conditions)32 (NS) Seyfried 2011 (but having an anxiolytic prescription was associated with suicide)35
Schizophrenia | | (+) llgen 2010 (men and women)25 (+) llgen 2010^26^ (+) llgen 2010^29^ (NS) Seyfried 2011^35^
Prior suicide attempt | (+) Hartl 2005^14^ (+) Thomsen 2011^36^
Social phobia | (+) Belik 2010^19^
Alcohol abuse | (+) Ilgen 2007^28^ (+) Belik 2010^19^ (NS) Tiet 2006^37^ | (+) llgen 2010 (men and women)25
Substance abuse | (+) Ilgen 2007 (cocaine)28 (NS) Tiet 2006^37^ (drug abuse or dependence) | (+) llgen 2010 (men and women)25 (+) Zivin 2007^41^
History of inpatient psychiatric hospitalization | | (+) Seyfried 2011^35^ (+) Zivin 2007 (within last 12 months)41
Negative life events | (+) Pettit 2006 (among those with very early onset MDD, very early onset anxiety and no history of very early onset psychopathology)42
Trauma and military factors
Traumatic Brain Injury (TBI) | (NS) Brenner 2011^21^ | (+) Brenner 2011^22^
Witnessing man-made disaster | (+) Belik 2009 (women only)18
Being a victim of child abuse or other abuse | (+) Belik 2009 (women only)18 (+) Cox 2011 (sexual abuse and other trauma)23
Witnessing domestic violence | (+) Belik 2009 (women only)18 (+) Cox 2011 (as a child)23
Being stalked | (+) Belik 2009^18^
Being mugged, being kidnapped | (+) Belik 2009 (men only)18
Having purposely injured or killed | (+) Belik 2009 (men only)18
Toxic chemical exposure | (+) Belik 2009 (men only)18
Life-threatening illness | (+) Belik 2009 (men only)18
Sexual abuse | (+) Tiet 2006 (past 30 days or lifetime)37 (+) Cox (childhood) (+) Belik 2009 (sexual assault or rape)18
Physical abuse in past 30 days | (+) Tiet 2006 (physical abuse in past 30 days)37 (NS) Tiet 2006 (lifetime physical abuse)37
Combat deployment | (NS) Thomsen 2011^36^
Traumatic event happened to another | (+) Belik 2009^18^
Other trauma | (+) Belik 2009 (men only)18
Being a civilian in a place where there was ongoing terror of civilians for political, ethnic, religious or other reasons) | (+) Belik 2009^18^
Non-service connected status for Veterans | | (+) Zivin 2007^41^
VA association (vs non-VA associated Veterans) | | (NS) Kaplan 2007 (all Veterans had higher risk of suicide regardless of VA affiliation)30
Other
Diabetes | | (+) Ilgen 2010^29^
Cerebrovascular disease | | (+) Ilgen 2010^29^
Lower mental health functioning (MCS-12 score) | | (+) Ilgen 2010^29^
Admission to nursing home | | (-) protective in Seyfried 2011^35^
Severe pain | | (+) Ilgen 2010^29^
Activity limitations | | (+) Kaplan 2007^30^

(+) positively associated with increase in suicide outcome (i.e., risk factor)

(-) negatively associated with increase in suicide outcomes (i.e., protective factor)

(NS) evaluated and found not to be significantly associated with the suicide outcome

Table 2 Summary of Risk Studies

Author, Year | Study Design/Analysis | Population | Outcome | Risk of Bias and main flaws
Belik 2009^18^ | Cross-sectional | 8,441 Canadian military personnel, active military within 6 months | Self-reported suicide attempt | Unclear
Belik 2010^19^ | Cross-sectional | 8,441 Canadian military personnel, active military within 6 months | Self-reported suicide attempt | Unclear
Bell 2010^20^ | Case control | 1,873 identified suicides from Army. | Suicide | Unclear
Brenner 2011^21^ (“Posttraumatic…”) | Case-control | Veterans receiving mental health services | EMR note of suicide attempt | Unclear
Brenner 2011^22^ (“Suicide…”) | Longitudinal | Veterans receiving mental health services | Suicide by ICD-10 | Unclear
Cox 2011^23^ | Cross-sectional | 656 men and women admitted to the psychiatry unit of a large US Army for suicidal thoughts or behaviors | Admission for suicide attempt | Unclear
Desai 2005^24^ | Longitudinal | 121,933 patients discharged from US VA hospital inpatient psychiatry wards with major affective disorder, bipolar disorder, PTSD or schizophrenia (481 suicides) | Suicide identified by ICD-9/10 and NDI, 1 year after inpatient discharge | Unclear
Hartl 2005^14^ | Longitudinal | 630 male Veterans with PTSD | Self-reported suicide attempt after discharge from the inpatient unit | Unclear
Ilgen 2007^28^ | Longitudinal | 8,807 Veterans enrolled in substance abuse programs | Self-reported suicide attempt within 30 days prior to the 1 year follow-up assessment | Unclear
Ilgen 2009^27^ | Longitudinal | 589,825 VA patients treated for depression | Suicide confirmed by NDI | Unclear
Ilgen 2010^25^ (“Psychiatric Diagnoses…”) | Longitudinal | All US Veterans (3,291,891) who used VA services during Fiscal Year (FY) 1999 and were alive at the start of FY 2000 | Suicide confirmed by NDI | Unclear
llgen 2010^29^ (“Severe Pain…”) | Longitudinal | 260,254 US Veterans who responded to the 1999 LHSV | Suicide confirmed by NDI | Unclear
llgen 2010^26^ (“Violent and Nonviolent Suicide…”) | Longitudinal | 5,082 US Veterans who were alive at the beginning of FY 2002 (854 suicides and 4,228 who did not die by suicide) | Suicide confirmed by NDI | Unclear
Kaplan 2007^30^ | Longitudinal | 104,026 male US Veterans | Suicide confirmed by NDI | Unclear
Mahon 2005^31^ | Case control | 732 death in Irish Defense Forces | Suicide by military files and proceedings of the Courts of Inquiry | Unclear
Pettit 2006^42^ | Cross-sectional | 298 military-based young adults at entry to treatment for suicidality | Self-report suicide attempt | Unclear
Pfeiffer 2009^32^ | Longitudinal | 887,889 US Veterans with depression | Suicides from NDI and ICD-10 | Unclear
Pinder 2011^33^ | Cross-sectional | 821 personnel who participated in the King's Centre for Military Health Research military health study (UK Armed Forces) | Self-report of lifetime suicide attempt or self-harm | High
Roy 2011^34^ | Case control | 40 US Veterans with prior substance abuse, currently abstinent | Self-report suicide attempt | High
Seyfried 2011^35^ | Longitudinal | 294,952 US Veterans | Suicide by NDI and ICD-10 | Low
Thomsen 2011^36^ | Cross-sectional | 2116 active duty military personnel serving at US Marine Corps installations | Self-report of suicide attempt | Unclear
Tiet 2006^37^ | Cross-sectional | 34,245 substance abuse patients from 150 US VA facilities | Self-report of suicide attempt in past 30 days by ASI | Unclear
Valenstein 2009^38^ | Longitudinal | 887,859 US Veterans with depression | Suicide using NDI | Unclear
Yerevanian 2007 - Part 2^40^ | Longitudinal | 405 Veterans with bipolar disorder | Suicidal behavior assessed by chart review | High
Yerevanian 2007 - Part 3^39^ | Longitudinal | 406 Veterans with bipolar disorder | Suicidal behavior assessed by chart review | High
Zivin 2007^41^ | Longitudinal | 807,694 US Veterans with depression | Suicide by NDI | Unclear