# REFERENCES

1 Kochanek KD, Xu J, Murphy SL, Miniño AM, Kung HC. Deaths: preliminary data for 2009. Natl Vital Stat Rep. 2011;59(4):1-51.
2 Reger MA, Luxton DD, Skopp NA, Lee JA, Gahm GA. Suicide Risk Management & Surveillance Office (SRMSO). Department of Defense Suicide Event Report (DoDSER): Calendar Year 2008 Annual Report. 2008.
3 Kang HK, Bullman TA. Risk of suicide among US veterans after returning from the Iraq or Afghanistan war zones. JAMA. Aug. 2008;300(6):652-3. [pmid: 18698062].
4 Mann JJ, Apter A, Bertolote J, et al. Suicide prevention strategies: a systematic review. JAMA. Oct. 26. 2005;294(16):2064-74. [pmid: 16249421].
5 Gaynes BN, West SL, Ford CA, et al. Screening for Suicide Risk in Adults: A Summary of the Evidence for the U.S. Preventive Services Task Force. Annals of Internal Medicine. May. 2004;140(10):822-35. [pmid: 15148072].
6 National Institute for Health and Clinical Excellence. Self-harm: longer-term management in adults, children and young people [Draft for Consultation]. National Collaborating Centre for Mental Health. 2011.
7 Shekelle P, Bagley S, Munjas B. Strategies for Suicide Prevention in Veterans. Evidence-based Synthesis Program. 2009. Jan.
8 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. Journal of Clinical Epidemiology. 1991;44(11):1271-8. [pmid: 1834807].
9 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
10 Hayden JA, Cote P, Bombardier C. Evaluation of the Quality of Prognosis Studies in Systematic Reviews. Annals of Internal Medicine March. 2006;144(6):427-37.
11 Brown GK. A Review of Suicide Assessment Measures for Intervention Research with Adults and Older Adults. Bethesda, MD. National Institute of Mental Health. 2002. http://www.hawaii.edu/hivandaids/Review%20of%20Suicide%20Assess%20for%20Interven%20Res%20w%20Adults%20and%20Older%20Adults.pdf. February 12.
12 Goldston DB. Assessment of suicidal behaviors and risk among children and adolescents. 2000.
13 Breshears RE, Brenner LA, Harwood JE, Gutierrez PM. Predicting suicidal behavior in veterans with traumatic brain injury: the utility of the personality assessment inventory. J Pers Assess. Jul. 2010;92(4):349-55. [pmid: 20552509].
14 Hartl TL, Rosen C, Drescher K, Lee TT, Gusman F. Predicting high-risk behaviors in veterans with posttraumatic stress disorder. J Nerv Ment Dis. Jul. 2005;193(7):464-72. [pmid: 15985841].
15 Hendin H, Al Jurdi RK, Houck PR, Hughes S, Turner J. Role of intense affects in predicting short-term risk for suicidal behavior: A prospective study. Journal of Nervous and Mental Disease. Mar. 2010;198(3):220-5. [pmid: 20216000].
16 Nademin E, Jobes DA, Pflanz SE, et al. An investigation of interpersonal-psychological variables in air force suicides: a controlled-comparison study. Arch Suicide Res. 2008;12(4):309-26. [pmid: 18828034].
17 Tiet QQ, Ilgen MA, Byrnes HF, Moos RH. Suicide attempts among substance use disorder patients: an initial step toward a decision tree for suicide management. Alcohol Clin Exp Res. Jun. 2006;30(6):998-1005. [pmid: 16737458].
18 Belik SL, Stein MB, Asmundson GJ, Sareen J. Relation between traumatic events and suicide attempts in Canadian military personnel. Can J Psychiatry. Feb. 2009;54(2):93-104. [pmid: 19254440].
19 Belik SL, Stein MB, Asmundson GJ, Sareen J. Are Canadian soldiers more likely to have suicidal ideation and suicide attempts than Canadian civilians?. Am J Epidemiol. Dec. 1. 2010;172(11):1250-8. [pmid: 20978087].
20 Bell NS, Harford TC, Amoroso PJ, Hollander IE, Kay AB. Prior health care utilization patterns and suicide among U.S. Army soldiers. Suicide Life Threat Behav. Aug. 2010;40(4):407-15. [pmid: 20822367].
21 Brenner LA, Betthauser LM, Homaifar BY, et al. Posttraumatic Stress Disorder, Traumatic Brain Injury, and Suicide Attempt History among Veterans Receiving Mental Health Services. Suicide Life Threat Behav. 2011. May. 20.
22 Brenner LA, Ignacio RV, Blow FC. Suicide and traumatic brain injury among individuals seeking Veterans Health Administration services. J Head Trauma Rehabil. Jul-Aug. 2011;26(4):257-64. [pmid: 21734509].
23 Cox DW, Ghahramanlou-Holloway M, Szeto EH, et al. Gender differences on documented trauma histories: inpatients admitted to a military psychiatric unit for suicide-related thoughts or behaviors. J Nerv Ment Dis. Mar. 2011;199(3):183-90. [pmid: 21346489].
24 Desai RA, Dausey DJ, Rosenheck RA. Mental Health Service Delivery and Suicide Risk: The Role of Individual Patient and Facility Factors. The American Journal of Psychiatry. Feb. 2005;162(2):311-8. [pmid: 15677596].
25 Ilgen MA, Bohnert AS, Ignacio RV, et al. Psychiatric diagnoses and risk of suicide in veterans. Arch Gen Psychiatry. Nov. 2010;67(11):1152-8. [pmid: 21041616].
26 Ilgen MA, Conner KR, Valenstein M, Austin K, Blow FC. Violent and nonviolent suicide in veterans with substance-use disorders. [erratum apperas in J Stud Alcohol Drugs 71 (5): 795]. J Stud Alcohol Drugs. Jul. 2010;71(4):473-9. [pmid: 20553655].
27 Ilgen MA, Downing K, Zivin K, et al. Exploratory data mining analysis identifying subgroups of patients with depression who are at high risk for suicide. J Clin Psychiatry. Nov. 2009;70(11):1495-500. [pmid: 20031094].
28 Ilgen MA, Harris AH, Moos RH, Tiet QQ. Predictors of a suicide attempt one year after entry into substance use disorder treatment. Alcohol Clin Exp Res. Apr. 2007;31(4):635-42. [pmid: 17374043].
29 Ilgen MA, Zivin K, Austin KL, et al. Severe pain predicts greater likelihood of subsequent suicide. Suicide Life Threat Behav. Dec. 2010;40(6):597-608. [pmid: 21198328].
30 Kaplan MS, Huguet N, McFarland BH, Newsom JT. Suicide among male veterans: a prospective population-based study. J Epidemiol Community Health. Jul. 2007;61(7):619-24. [pmid: 17568055].
31 Mahon MJ, Tobin JP, Cusack DA, Kelleher C, Malone KM. Suicide among regular-duty military personnel: a retrospective case-control study of occupation-specific risk factors for workplace suicide. Am J Psychiatry. Sep. 2005;162(9):1688-96. [pmid: 16135629].
32 Pfeiffer PN, Ganoczy D, Ilgen M, Zivin K, Valenstein M. Comorbid anxiety as a suicide risk factor among depressed veterans. Depress Anxiety. 2009;26(8):752-7. [pmid: 19544314].
33 Pinder RJ, Iversen AC, Kapur N, Wessely S, Fear NT. Self-harm and attempted suicide among UK Armed Forces personnel: Results of a cross-sectional survey. Int J Soc Psychiatry. 2011. Jun. 21.
34 Roy A, Carli V, Sarchiapone M. Resilience mitigates the suicide risk associated with childhood trauma. J Affect Disord. 2011. May. 27.
35 Seyfried LS, Kales HC, Ignacio RV, Conwell Y, Valenstein M. Predictors of suicide in patients with dementia. Alzheimers Dement. Nov. 2011;7(6):567-73. [pmid: 22055973].
36 Thomsen CJ, Stander VA, McWhorter SK, Rabenhorst MM, Milner JS. Effects of combat deployment on risky and self-destructive behavior among active duty military personnel. J Psychiatr Res. 2011. May. 4.
37 Tiet QQ, Finney JW, Moos RH. Recent sexual abuse, physical abuse, and suicide attempts among male veterans seeking psychiatric treatment. Psychiatr Serv. Jan. 2006;57(1):107-13. [pmid: 16399970].
38 Valenstein M, Kim HM, Ganoczy D, et al. Higher-risk periods for suicide among VA patients receiving depression treatment: prioritizing suicide prevention efforts. J Affect Disord. Jan. 2009;112(1-3):50-8. [pmid: 18945495].
39 Yerevanian BI, Koek RJ, Mintz J. Bipolar pharmacotherapy and suicidal behavior Part 3: impact of antipsychotics. J Affect Disord. Nov. 2007;103(1-3):23-8. [pmid: 17604119].
40 Yerevanian BI, Koek RJ, Mintz J, Akiskal HS. Bipolar pharmacotherapy and suicidal behavior Part 2. The impact of antidepressants. J Affect Disord. Nov. 2007;103(1-3):13-21. [pmid: 17617467].
41 Zivin K, Kim HM, McCarthy JF, et al. Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: associations with patient and treatment setting characteristics. Am J Public Health. Dec. 2007;97(12):2193-8. [pmid: 17971541].
42 Pettit JW, Paukert AL, Joiner TE Jr., Rudd MD. Pilot sample of very early onset bipolar disorder in a military population moderates the association of negative life events and non-fatal suicide attempt. Bipolar Disord. Oct. 2006;8(5 Pt 1):475-84. [pmid: 17042885].
43 Centers for Disease Control and Prevention (CDC). Suicide facts at a glance. National Center for Injury Prevention and Control. 2009. Available at http://www.cdc.gov/violenceprevention/pdf/Suicide-DataSheet-a.pdf. 1/3/2012.
44 Goldsmith SK, Pelmar TC, Kleinman AM, Bunny WE, editors. Reducing suicide: A national imperative. Washington (DC). National Academy Press. 2002.
45 Nock MK, Borges G, Bromet EJ, Cha CB, Kessler RC, Lee S. Suicide and suicidal behavior. Epidemiol Rev. 2008;30:133-54. [pmid: 18653727].
46 Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. National Violent Death Reporting System: Monitoring and Tracking the Causes of Violent Deaths - 2008. 2008. http://www.cdph.ca.gov/programs/Documents/nvdrs_aag_2008-a.pdf. February 29, 2012.
47 McCarthy JF, Valenstein M, Kim HM, Ilgen M, Zivin K, Blow FC. Suicide mortality among patients receiving care in the veterans health administration health system. American journal of epidemiology. Apr. 15. 2009;169(8):1033-8. [pmid: 19251753].
48 Blow FC, Bohnert ASB, Ilgen MA, et al. Suicide Mortality Among Patients Treated by the Veterans Health Administration From 2000 to 2007. American Journal of Public Health. 2012;102(S1):S98-S104. [pmid: 22390612].
49 Kuehn BM. Soldier suicide rates continue to rise: military, scientists work to stem the tide. JAMA. Mar. 18. 2009;301(11):1111-3. [pmid: 19293405].
50 Department of Veterans Affairs. Screening and evaluation of possible traumatic brain injury in operation enduring freedom (OEF) and operation Iraqi freedom (OIF) veterans. VHA Directive 2007-013. 2007.
51 Department of Veterans Affairs. Report of the Blue Ribbon Work Group on Suicide Prevention in the Veteran Population. 2008. Available at http://www.mentalhealth.va.gov/suicide_prevention/Blue_Ribbon_Report-FINAL_June-30-08.pdf. January 3, 2012.
52 US Public Health Service. The Surgeon General's Call to Action to Prevent Suicide. Washington, D.C. 1999.
53 World Health Organization. SUPRE Prevention of suicidal behaviors: a task for all. 2007. Available at http://www.who.int/mental_health/prevention/suicide/information/en/index.html. January 3, 2012.
54 Luoma J, Martin C, Pearson J. Contact with mental health and primary care providers before suicide: A review of the evidence. American Journal of Psychiatry. 2002;159(6):909-16. [pmid: 12042175].
55 Basham C, Denneson LM, Millet L, Shen X, Duckart J, Dobscha SK. Characteristics and VA Health Care Utilization of U. S. Veterans Who Completed Suicide in Oregon Between 2000 and 2005. Suicide Life Threat Behav. Apr. 4. 2011;42(3):287-96. [pmid: 21463353].
56 Schulberg HC, Bruce ML, Lee PW, Williams JWJ, Dietrich AJ. Preventing suicide in primary care patients: the primary care physician's role. Gen Hosp Psychiatry. 2004;26(5):337-45. [pmid: 15474633].
57 Bajaj P, Borreani E, Ghosh P, Methuen C, Patel M, Crawford MJ. Screening for suicidal thoughts in primary care: the views of patients and general practitioners. Ment Health Fam Med. 2008;5(4):229-35. [pmid: 22477874].
58 Lambert MT. Seven-year outcomes of patients evaluated for suicidality. Psychiatr Serv. 2002;53(1):92-4. [pmid: 11773656].
59 Lambert MT, Fowler DR. Suicide risk factors among veterans: risk management in the changing culture of the Department of Veterans Affairs. J Ment Health Adm. 1997;24(3):350-8. [pmid: 9230576].
60 Martin J, Ghahramanlou-Holloway M, Lou K, Tucciarone P. A comparative review of U.S. Military and civilian suicide behavior: Implications for OEF/OIF suicide prevention efforts. Journal of Mental Health and Counseling. 2009;31(2):101-18.
61 Cavanagh J, Carson A, Sharpe M, L SM. Psychological autopsy studies of suicide: A systematic review. Psychological Medicine. 2003;33:395-405. [pmid: 12701661].
62 Zamorski MA. Suicide prevention in military organizations. Int Rev Psychiatry. Apr. 2011;23(2):173-80. [pmid: 21521087].
63 Teasdale T, Engberg A. Suicide after traumatic brain injury: a population study. Journal of Neurology, Neurosurgery & Psychiatry. 2001;71(4):436-40.
64 Joiner T. Why people die by suicide. Cambridge. Harvard University Press. 2005.
65 Brenner LA, Gutierrez PM, Cornette MM, Betthauser LM, Bahraini N, Staves PJ. A Qualitative study of potential suicide risk factors in returning combat veterans. Journal of Mental Health Counseling. Jul. 2008;30(3):211-25.
66 Brenner LA, Breshears RE, Betthauser LM, et al. Implementation of a Suicide Nomenclature within Two VA Healthcare Settings. J Clin Psychol Med Settings. Jun. 2011;18(2):116-28. [pmid: 21626353].
67 Centers for Disease Control and Prevention, Crosby AE, Han B, et al. Suicidal thoughts and behaviors among adults aged ≥18 years --- United States, 2008-2009. MMWR Surveill Summ. Oct. 21. 2011;60(13):1-22. [pmid: 22012169].
68 Kutcher S, Szumilas M. Controlling for known risk factors for suicide in multivariate models. Can J Psychiatry. Apr. 2010;55(4):269. author reply 70. [pmid: 20422783].
69 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
70 Moher D, Liberati A, Tetzlaff J, Altman DG, The Prisma Group. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
71 Bhui K, McKenzie K, Rasul F. Rates, risk factors & methods of self harm among minority ethnic groups in the UK: a systematic review. BMC Public Health. 2007;7:336. [pmid: 18021438].
72 Borschmann R, Hogg J, Phillips R, Moran P. Measuring self-harm in adults: A systematic review. Eur Psychiatry. 2011. Jun. 20.
73 Bowers L, Banda T, Nijman H. Suicide inside: a systematic review of inpatient suicides. J Nerv Ment Dis. May. 2010;198(5):315-28. [pmid: 20458192].
74 Bridge JA, Iyengar S, Salary CB, et al. Clinical response and risk for reported suicidal ideation and suicide attempts in pediatric antidepressant treatment: a meta-analysis of randomized controlled trials. JAMA. Apr. 18. 2007;297(15):1683-96. [pmid: 17440145].
75 Burrows S, Laflamme L. Socioeconomic disparities and attempted suicide: state of knowledge and implications for research and prevention. Int J Inj Contr Saf Promot. Mar. 2010;17(1):23-40. [pmid: 19830604].
76 Calabria B, Degenhardt L, Hall W, Lynskey M. Does cannabis use increase the risk of death? Systematic review of epidemiological evidence on adverse effects of cannabis use. Drug Alcohol Rev. May. 2010;29(3):318-30. [pmid: 20565525].
77 Calati R, Porcelli S, Giegling I, et al. Catechol-o-methyltransferase gene modulation on suicidal behavior and personality traits: Review, meta-analysis and association study. Journal of Psychiatric Research. Mar. 2011;45(3):309-21. [pmid: 20667552].
78 Carpenter DJ, Fong R, Kraus JE, Davies JT, Moore C, Thase ME. Meta-analysis of efficacy and treatment-emergent suicidality in adults by psychiatric indication and age subgroup following initiation of paroxetine therapy: a complete set of randomized placebo-controlled trials. J Clin Psychiatry. 2011. Feb. 22.
79 Chen LP, Murad MH, Paras ML, et al. Sexual abuse and lifetime diagnosis of psychiatric disorders: systematic review and meta-analysis. Mayo Clin Proc. Jul. 2010;85(7):618-29. [pmid: 20458101].
80 Goldman-Mellor SJ, Saxton KB, Catalano RC. Economic contraction and mental health: A review of the evidence, 1990-2009. International Journal of Mental Health. Sum. 2010;39(2):6-31.
81 Hammerness PG, Vivas FM, Geller DA. Selective serotonin reuptake inhibitors in pediatric psychopharmacology: a review of the evidence. J Pediatr. Feb. 2006;148(2):158-65. [pmid: 16492422].
82 Haw C, Hawton K, Sutton L, Sinclair J, Deeks J. Schizophrenia and Deliberate Self- Harm: A Systematic Review of Risk Factors. Suicide and Life Threatening Behavior. Feb. 2005;35(1):50-62. [pmid: 15843323].
83 Hawton K, Sutton L, Haw C, Sinclair J, Harriss L. Suicide and attempted suicide in bipolar disorder: a systematic review of risk factors. J Clin Psychiatry. Jun. 2005;66(6):693-704. [pmid: 15960561].
84 Hor K, Taylor M. Suicide and schizophrenia: a systematic review of rates and risk factors. J Psychopharmacol. Nov. 2010;24(4 Suppl):81-90. [pmid: 20923923].
85 Innamorati M, Pompili M, Amore M, et al. Suicide prevention in late life: Is there sound evidence for practice?. Pompili M, Tatarelli R, editors. Evidence-based practice in suicidology: A source book. Cambridge, MA. Hogrefe Publishing. 2011:211-32.
86 Kallert TW, Glockner M, Schutzwohl M. Involuntary vs. voluntary hospital admission. A systematic literature review on outcome diversity. Eur Arch Psychiatry Clin Neurosci. Jun. 2008;258(4):195-209. [pmid: 18080170].
87 Kim YS, Leventhal B. Bullying and suicide. A review. Int J Adolesc Med Health. Apr-Jun. 2008;20(2):133-54. [pmid: 18714552].
88 King M, Semlyen J, Tai SS, et al. A systematic review of mental disorder, suicide, and deliberate self harm in lesbian, gay and bisexual people. BMC Psychiatry. 2008;8:70. [pmid: 18706118].
89 Large M, Smith G, Sharma S, Nielssen O, Singh SP. Systematic review and meta-analysis of the clinical factors associated with the suicide of psychiatric in-patients. Acta Psychiatr Scand. Jul. 2011;124(1):18-29. [pmid: 21261599].
90 Lemon DD. Killing me softly: A meta-analysis examining risk factors associated with suicide among young African American males. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;69(10-B):6420.
91 Maniglio R. The role of child sexual abuse in the etiology of suicide and non-suicidal self-injury. Acta Psychiatr Scand. Jul. 2011;124(1):30-41. [pmid: 20946202].
92 McMillan D, Gilbody S, Beresford E, Neilly L. Can we predict suicide and non-fatal self-harm with the Beck Hopelessness Scale? A meta-analysis. Psychol Med. Jun. 2007;37(6):769-78. [pmid: 17202001].
93 Mironova P, Rhodes AE, Bethell JM, et al. Childhood physical abuse and suicide-related behavior: A systematic review. Vulnerable Children and Youth Studies. Mar. 2011;6(1):1-7.
94 O'Connor EA, Whitlock EP, Beil TL, Gaynes BN. Screening for depression in adult patients in primary care settings: a systematic evidence review. Ann Intern Med. Dec. 1. 2009;151(11):793-803. [pmid: 19949145].
95 O'Connor EA, Whitlock EP, Gaynes B, Beil TL. Screening for Depression in Adults and Older Adults in Primary Care: An Updated Systematic Review. 2009. Dec. Systematic Review.
96 Perry AE, Marandos R, Coulton S, Johnson M. Screening tools assessing risk of suicide and self-harm in adult offenders: a systematic review. Int J Offender Ther Comp Criminol. Oct. 2010;54(5):803-28. [pmid: 20223913].
97 Platt B, Hawton K, Simkin S, Mellanby RJ. Systematic review of the prevalence of suicide in veterinary surgeons. Occup Med (Lond). Sep. 2010;60(6):436-46. [pmid: 20591857].
98 Rhodes AE, Boyle MH, Tonmyr L, et al. Sex differences in childhood sexual abuse and suicide-related behaviors. Suicide Life Threat Behav. Jun. 2011;41(3):235-54. [pmid: 21477094].
99 Rowell K, Green B, Guidry J, Eddy J. Factors associated with suicide among African American adult men: A systematic review of the literature. Journal of Men's Health. Dec. 2008;5(4):274-81.
100 Sakinofsky I. Treating suicidality in depressive illness. Part 2: does treatment cure or cause suicidality?. Can J Psychiatry. Jun. 2007;52(6 Suppl 1):85S-101S. [pmid: 17824355].
101 Sakinofsky I. Treating suicidality in depressive illness. Part 1: current controversies. Can J Psychiatry. Jun. 2007;52(6 Suppl 1):71S-84S. [pmid: 17824354].
102 Sakinofsky I. The current evidence base for the clinical care of suicidal patients: strengths and weaknesses. Can J Psychiatry. Jun. 2007;52(6 Suppl 1):7S-20S. [pmid: 17824349].
103 Spiegel B, Schoenfeld P, Naliboff B. Systematic review: the prevalence of suicidal behaviour in patients with chronic abdominal pain and irritable bowel syndrome. Aliment Pharmacol Ther. Jul. 15. 2007;26(2):183-93. [pmid: 17593064].
104 State of Victoria Department of Health. Suicide risk assessment and management: A systematic evidence review for the Clinical practice guidelines for emergency departments and mental health services project. Mental Health, Drugs and Regions Division. 2010.
105 Van Lieshout RJ, MacQueen GM. Efficacy and acceptability of mood stabilisers in the treatment of acute bipolar depression: systematic review. Br J Psychiatry. Apr. 2010;196:266-73. [pmid: 20357301].
106 Weich S, Patterson J, Shaw R, Stewart-Brown S. Family relationships in childhood and common psychiatric disorders in later life: systematic review of prospective studies. Br J Psychiatry. May. 2009;194(5):392-8. [pmid: 19407266].
107 Williams SB, O'Connor E, Eder M, Whitlock E. Screening for Child and Adolescent Depression In Primary Care Settings: A Systematic Evidence Review for the U.S. Preventive Services Task Force. 2009. Apr.
108 Williams SB, O'Connor EA, Eder M, Whitlock EP. Screening for child and adolescent depression in primary care settings: a systematic evidence review for the US Preventive Services Task Force. Pediatrics. Apr. 2009;123(4):e716-35. [pmid: 19336361].
109 McLellan AT, Kushner H, Metzger D, et al. The Fifth Edition of the Addiction Severity Index. Journal of Substance Abuse Treatment. 1992;9(3):199-213. [pmid: 1334156].
110 Huth-Bocks AC, Kerr DC, Ivey AZ, Kramer AC, King CA. Assessment of psychiatrically hospitalized suicidal adolescents: self-report instruments as predictors of suicidal thoughts and behavior. J Am Acad Child Adolesc Psychiatry. Mar. 2007;46(3):387-95. [pmid: 17314725].
111 Harriss L, Hawton K. Suicidal intent in deliberate self-harm and the risk of suicide: The predictive power of the Suicide Intent Scale. Journal of Affective Disorders. Jun. 2005;86(2-3):225-33. [pmid: 15935242].
112 Harriss L, Hawton K, Zahl D. Value of measuring suicidal intent in the assessment of people attending hospital following self-poisoning or self-injury. British Journal of Psychiatry. Jan. 2005;186(1):60-6. [pmid: 15630125].
113 Gutierrez PM, Osman A. Getting the best return on your screening investment: An analysis of the Suicidal Ideation Questionnaire and Reynolds Adolescent Depression Scale. School Psychology Review. 2009;38(2):200-17.
114 Naud H, Daigle MS. Predictive validity of the Suicide Probability Scale in a male inmate population. Journal of Psychopathology and Behavioral Assessment. Sep. 2010;32(3):333-42.
115 Cooper J, Kapur N, Dunning J, Guthrie E, Appleby L, Mackway-Jones K. A clinical tool for assessing risk after self-harm. Ann Emerg Med. Oct. 2006;48(4):459-66. [pmid: 16997684].
116 Daigle MS, Labelle R, Cote G. Further evidence of the validity of the Suicide Risk Assessment Scale for prisoners. Int J Law Psychiatry. Sep-Oct. 2006;29(5):343-54. [pmid: 16759704].
117 Healy DJ, Barry K, Blow F, Welsh D, Milner KK. Routine use of the Beck Scale for Suicide Ideation in a psychiatric emergency department. Gen Hosp Psychiatry. Jul-Aug. 2006;28(4):323-9. [pmid: 16814632].
118 Walker J, Hansen CH, Hodges L, et al. Screening for suicidality in cancer patients using Item 9 of the nine-item patient health questionnaire; does the item score predict who requires further assessment?. Gen Hosp Psychiatry. Mar-Apr. 2010;32(2):218-20. [pmid: 20302999].
119 Walker J, Hansen CH, Butcher I, et al. Thoughts of death and suicide reported by cancer patients who endorsed the “suicidal thoughts” item of the PHQ-9 during routine screening for depression. Psychosomatics. Sep-Oct. 2011;52(5):424-7. [pmid: 21907060].
120 Thompson R, Henkel V, Coyne JC, Goodwin RD, Kroenke K. Letter to the Editor (with response): Suicidal ideation in primary care: Ask a vague question, get a confusing answer. Psychosomatic Medicine. 2004;66:455-7. [pmid: 15184710].