# METHODS

## TOPIC DEVELOPMENT

This project was requested by the VA/Department of Defense (DoD) Evidence Based Practice Working Group (EBPWG) to support the development of clinical practice guidelines for suicide prevention. The VA/DoD suicide prevention EBPWG requested a systematic review of literature related to suicidal self-directed violence as denned by Crosby et al. and Brenner et al.66, 67 published since two prior reports on the topic by Mann et al. and Gaynes et al.4, 5 The workgroup requested a review that focuses on countries and populations most representative of US Veteran and military populations.

A report on self-harm was recently conducted by the National Institute for Health and Clinical Excellence (NICE) and released in draft form during the writing of this current report.6 The NICE report focuses on self-harm in general within the civilian population. Our report examines suicidal self-directed violence specifically rather than self-harm in general, and focuses on US Veterans and members of the military rather than on a civilian population. To be comprehensive, we summarize findings from the earlier (Mann and Gaynes) and concurrent (NICE) reviews in our report to highlight broader, civilian-focused evidence, though our report focuses on evidence specifically related to Veterans and members of the military. A technical panel comprised of members of this workgroup as well as VA leaders in the field of suicidology provided input.

The final key questions developed a priori in conjunction with the EBPWG are:

- Key Question #1. What assessment tools are effective for assessing risk of engaging in suicidal self-directed violence in Veteran and military populations?
- Key Question #2. In addition to the risk factors included by current assessment tools, what other risk factors predict suicidal self-directed violence in Veteran and military populations?

## SEARCH STRATEGY

To identify relevant systematic reviews and controlled trials, we searched PubMed, PsycINFO, the Cochrane Database of Systematic Reviews^®^, and the Cochrane Central Register of Controlled Trials^®^. We used a similar search strategy as Mann et al.,4 and covered the period from January 2005 to November 18, 2011 to identify newer studies that would not have been included in this prior review. We also included risk assessment, screening and validity, and Veteran populations as search terms (Appendix A). We limited the search to peer-reviewed articles involving human subjects and published in the English language that were not included in previously published systematic reviews on the topic.4, 5 We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and consulting experts. Additionally, though the focus of the requested review was on risk factors and assessment tools related to suicide, we included any articles reporting on suicidal self-directed violence as an outcome to include as comprehensive a list of articles as possible.

## STUDY SELECTION

Titles and abstracts were reviewed by doctoral level investigators and project research associates trained in the critical analysis of literature. Eligibility of full-text articles was independently assessed by two reviewers, and disagreements were resolved by consensus.

To determine the evidence base for the assessment of risk for engaging in suicidal self-directed violence and identifying additional risk factors for suicidal self-directed violence, we examined studies with any design, including systematic reviews, randomized controlled trials, observational studies and case control analyses. Assessment of new or emerging risk factors requires evaluation within the context of previously known risk factors. Some new risk factors may act through or as a result of other existing risk factors. Thus, controlling for known risk factors is an essential part of any study that seeks to propose a new clinical risk factor.68 As such, we have included here only studies that evaluate risk factors using analytic techniques that account for at least one of several well-established risk factors (established a priori): suicidal ideation, history of suicide attempts, substance use disorder, or history of any mental health diagnosis. Therefore, studies that only reported rates of suicide in a general population were excluded; however, studies reporting rates of suicide in a population of people who all had prior substance use disorders or mental health diagnoses were included. Likewise, if a study enrolled patients from a randomized controlled trial and failed to control for treatment allocation, it was excluded. We excluded studies that used genetic testing to predict suicide, and studies that evaluated post-mortem tissue to assess biochemical or pathologic correlates with suicide. Our review was designed to detect the highest quality recent evidence relating to populations that most closely approximate US Veteran and military populations. Therefore, though we used selection criteria similar to those used in the reviews by Mann et al., Gaynes et al., and NICE 2011,^4-6^ our review differs from these reviews in excluding research conducted in countries dissimilar to the US, and excluding studies on civilian populations. Additionally, the NICE report addresses primarily risk assessment and risk factors related to repetition of self-harm.

Below are listed the specific inclusion criteria used to select studies for each Key Question, respectively:

- Key Question #1 – Primary literature review of studies with the following characteristics:
- Patients: Any Veteran and/or military patient subgroup from the US, United Kingdom (UK), Canada, New Zealand, and Australia.
- Intervention: Not applicable to this key question.
- Comparator: No intention to limit by comparator.
- Outcomes and measures: (1) Proportion of individuals in each risk group who exhibit suicidal self-directed violence, including suicide attempt and suicide and not including self-directed violence ideation and undetermined or non-suicidal self-directed violence (i.e., behavior resulting in injury for which there is unclear or no implicit or explicit evidence of intent to die); and (2) standard measures of discrimination and reclassification for risk assessment tools.
- Timing: Any length of follow-up.
- Setting: US Veteran or military inpatient or outpatient setting.

Key Question #2 – Primary literature review of studies with the following characteristics:

- Patients: Any Veteran and/or military patient subgroup from the US, UK, Canada, New Zealand, and Australia.
- Intervention: Not applicable to this key question.
- Comparator: No intention to limit by comparator.
- Outcomes and measures: Proportions or relative risk (RR) ratios for suicidal self-directed violence, including suicide attempt and suicide and not including self-directed violence ideation and undetermined or non-suicidal self-directed violence (i.e., behavior resulting in injury for which there is unclear or no implicit or explicit evidence of intent to die).
- Timing: Any length of follow-up.
- Setting: US Veteran or military inpatient or outpatient setting.
- The complete study selection form, including abstract and full-text codes, is included in Appendix B.

## DATA ABSTRACTION

For controlled trials, we abstracted information on setting, population characteristics, risk factors measured or included in assessment tool, comparison group (if any), number of subjects, length of follow-up, outcome assessment methods, and results. For systematic reviews, we abstracted information on the objective of the review, time period and databases searched, excluded studies and eligibility criteria used; and for all included studies that also met our eligibility criteria, we also abstracted information on study designs, country, sample size, population, and main results. For observational studies analyzing assessment tools, we abstracted information on study design, population and setting, outcome, risk factor included in assessment calculation, results, results of validation in a second group, and appropriateness for primary care settings. For observational studies assessing risk factors, we abstracted information on study design, aim of the study, sample size, data source and sample time frame, population characteristics, comparison group (if any), risk factors measured, method of measurement of risk factors and outcome, length of follow-up/observational, statistical analysis methods/control for confounding, and results.

## QUALITY ASSESSMENT

We assessed the quality of systematic reviews using predefined criteria established by Oxman and Guyatt in 1991.^8^ The Oxman and Guyatt quality rating system consists of nine questions that involve assessing the adequacy of systematic review methods including searching, reporting of inclusion criteria, study selection, validity assessment, data synthesis, and conclusions. Each question is scored as ‘yes,’ ‘partially/unclear,’ or ‘no’. The overall quality is scored based on a scale of 1 to 7, where 1 represents the presence of extensive flaws and 7 represents the presence of minimal flaws (Appendix C).

We assessed the risk of bias of primary studies using modified versions of the tools described in Harris et al. 2001 and Hayden et al. 2006.^9, 10^ Adequacy for each domain was rated as ‘yes,’ ‘unclear/unsure,’ or ‘no.’ The overall risk of bias for each controlled trial is then rated as ‘low,’ ‘unclear,’ or ‘high’ based on the reviewer's judgment of the plausibility that the biases have seriously weakened their confidence in the results (Appendices D and E).

Two reviewers independently assessed the quality of each study. Reviewers then compared their ratings and resolved all differences through discussion or by consulting a third party when consensus could not be reached. Note that it is possible for a study that is included in both the risk assessment tool section and the risk factor section (example, Hartl 2005) to be rated differently for risk of bias as the evidence pertains to each section because of differences in the risk of bias criteria for risk assessment studies versus risk factor studies. Domains for risk factor studies included: adequacy of population description, non-biased selection, minimal loss to follow-up, adequate (un-biased) risk factor assessment, adequate (un-biased) outcome measurement, adequate sample size (number of outcome events), adequate statistical adjustment, and number of confounders adjusted for in the analysis (must have adjusted for at least 1 of 4 necessary risk factors – any mental health diagnosis, history of suicide attempt, suicidal ideation or substance abuse). Domains for risk assessment tool studies included: adequate population description, non-biased selection, minimal loss to follow-up, standardized method of risk factor assessment and scoring clearly described, unbiased risk factor assessment by independent assessors, adequate outcome measurement, unbiased outcome measured by independent assessors, and adequate accounting for potential confounders.

## DATA SYNTHESIS

We constructed evidence tables showing study design, population and setting, and risk factor measured or included in assessment; methodological quality; and outcomes, organized by key question and study design. We analyzed studies to compare their characteristics, methods, and findings. For risk assessment tools, we graded strength of evidence based on the guidance established for the Evidence-based Practice Center Program of the Agency for Healthcare Research and Quality.69 We compiled a summary of findings for each key question and study design based on qualitative synthesis of the findings. The heterogeneity in study population, tool characteristics, and patient population among studies precluded meaningful quantitative analysis. For risk factor studies, we summarized the studies in a table displaying population, outcome and risk of bias (Table 2); we compiled the evidence about risk factors into a table that lists the strength of evidence according to each risk factor (Table 1).

We also report findings as described in the prior systematic reviews by Mann et al. and Gaynes et al.4, 5 Because our review was designed to be an update to these reports and because of different scopes of the reports, we have not re-evaluated the source studies included in their reports. Additionally, we include in our synthesis findings from the NICE 2011 draft report on self-harm,6 a review with a similarly up-to-date literature search to this current report, though a more broad focus on self-harm in all populations including civilians. Due to the differences in scope and methods in these other reports, data synthesis of their findings is limited to a qualitative summary of findings.

Our review was designed only to examine studies published since June, 2005, so we consider the findings from the Mann et al. and Gaynes et al. reviews to assess the contributions of pre-2005 literature on the overall strength of evidence.4, 5 We also summarize the information on repeated self-harm (including suicide) reported in the NICE 2011 review.6 However, because these reviews used different quality assessment and data synthesis methodology, as well as having different scopes (e.g., including civilian populations, or focusing on repeated self-harm), the combination of results from the reports should be interpreted with caution.

## PEER REVIEW

A draft version of this report was reviewed by seven technical experts as well as clinical leadership. Their comments and our responses are presented in Appendix M.