# INTRODUCTION

Suicide is a major public health concern in the United States (US), claiming over 36,000 lives each year and nearly 100 lives each day.1 Suicide was the tenth leading cause of death in the US in 2009.^1^ The rate is highest among 25 to 34 year-olds, for whom suicide is the second leading cause of death.43 For each suicide death, there are approximately 25 suicide attempts, also referred to as incidents of suicidal self-directed violence.44, 45 The lifetime risk of suicidal self-directed violence for the general US population is estimated to be between 1.9 and 8.7 percent.45

Among Veterans and current military, suicide is a national public health concern. Recent estimates suggest current or former military represent 20 percent of all known suicides in the US,46 and the rate of suicides among Veterans utilizing Veterans Health Administration (VHA) services is estimated to be higher than the general population.47, 48 Among active duty soldiers in the Army, Army Reserve, and Army National Guard, rates are increasing and reached 20.2 per 100,000 in 2008.^49^ Veterans returning from the Iraq and Afghanistan conflicts, referred to as Operation Enduring Freedom/Operation Iraqi Freedom (OEF/OIF) Veterans, may be particularly at risk, although the limited available data has shown mixed results.2, 3 The enormity of the problem has led to several major public health initiatives and growing interest in suicide and self-directed violence prevention.50-53

Approximately 32 percent of individuals make contact with a mental health care provider and 77 percent make contact with a primary care provider during the year prior to suicide.54 In one Oregon study, 22 percent of Veterans who died by suicide had made contact with Veterans Affairs (VA) healthcare providers in the prior year.55

Although healthcare providers have an opportunity to identify at-risk individuals and engage them in treatment to reduce suicidal self-directed violence, many healthcare providers are uncertain how to assess for suicide risk.56, 57 Several risk factors for suicide and suicidal self-directed violence have been identified, most notably older age, male gender, physical and mental health disorders (including depression and substance use disorders), familial and genetic influences, impulsivity, poor psychosocial support, and access to and knowledge of firearms.56, 58-60 Several psychological autopsy studies of the events leading up to suicide have suggested the majority of individuals who die by suicide exhibit symptoms of depression or other mental health issues prior to death.61

The relative importance of some of these traditional risk factors, as well as the influence of population-specific risk factors, may be unique among military personnel and Veterans. The prevailing male demographic, along with high rates of post-traumatic stress disorder (PTSD), substance use disorders, and other mental health disorders, may especially contribute to the risk of suicidal self-directed violence in military and Veteran populations. In addition, several aspects of military experience can increase the risk for mental health and substance abuse, which in turn are risk factors for suicide.62 Other risk factors unique to the military experience could also contribute to overall suicide risk, including military rank, combat exposure, traumatic brain injury (TBI),22, 63 habituation to violence,64 and deployment-related stressors (e.g., strained or long distance relationships, relocation, post-deployment adjustment).60, 65

Of course, many military and Veteran personnel will have one or more of these individual risk factors, but relatively few of them are truly at-risk for suicidal self-directed violence. Suicide risk assessment tools need to account for the relationship among these different risk factors and identify risk factors or combinations of risk factors that are particularly associated with suicidal self-directed violence. To be practically useful, risk assessment tools would identify a threshold beyond which preventive action should be taken and be brief enough to be conducted in primary care settings where many of the at-risk persons may be seen. Ideally, such tools would identify all persons truly at-risk for suicidal self-directed violence (i.e., have high sensitivity), while minimizing misidentification of persons who are not truly at high-risk (i.e., high specificity) because subsequent preventive therapies may be time-consuming and costly. Risk assessment tools should be able to, in other words, discriminate those at high- and low-risk for suicidal self-directed violence. Given the rarity of suicide, this can be a difficult task. Estimates by Gaynes et al. suggest that under base-case scenario, with an assessment tool with 0.80 sensitivity and 0.70 specificity applied to 10,000 patients (10 of whom will attempt suicide),5 will have a positive predictive value of 0.3 percent (8 true-positives, 2 false-negatives and 2,997 false-positives). Using a tool with 0.89 sensitivity raises the positive predictive value to 3.8 percent.5 These challenges require an enhanced understanding of suicide risk assessment in military and Veteran populations. The objectives of this review, therefore, are to review the available evidence for risk factors and assessment tools developed for use in healthcare and other community settings, and tested with Veteran and military populations.

## ANALYTICAL FRAMEWORK AND SCOPE OF THIS REPORT

In order to provide evidence for clinical practice guideline development, this report reviews available evidence about risk factors and risk assessment tools within Veteran and military populations.

The model below (Figure 1) summarizes the analytical framework used in this report for Veteran and military populations. We focus on individual-level risk factor determination and assessment; that is, clinically relevant risk factors that can help a provider determine that a patient has increased risk, and assessment tools that are appropriate for clinical risk assessment to predict suicide outcomes. Though the focus of the report is on suicide prevention, we include as outcomes any type of suicidal self-directed violence defined as, “Behavior that is self-directed and deliberately results in injury or the potential for injury to oneself. There is evidence, whether implicit or explicit, of suicidal intent.”66, 67 We use this terminology throughout this evidence report when possible; however, when describing results from primary studies, we use terminology as reported in the original articles in order to describe outcomes consistent with the primary studies.

Figure 1 Suicide Prevention Analytical Model